# RESULTS

## DEFINITIONS OF HOMELESSNESS

The current definition of a “homeless Veteran” combines both Veteran status and homeless status. The VA considers a Veteran as a person who “served in the active military, naval, or air service” and was not dishonorably discharged. However, many studies of homeless Veterans include as a Veteran anyone who reports having served in the military, regardless of active duty or discharge status. Reported Veteran status is rarely confirmed through a review of VA administrative data. Veterans are considered homeless if they meet the definition of “homeless individual” established by the McKinney-Vento Homeless Act (P.L. 100-77). The McKinney-Vento Act defines a homeless individual as an individual who lacks a fixed, regular, and adequate nighttime residence, and a person who had a nighttime residence that is: a supervised publically or privately operated shelter designed to provide temporary living accommodations; an institution that provides a temporary residence for individuals intended to be institutionalized; or a public or private place not designed for or ordinarily used as a regular sleeping accommodation for human beings.16

The current definition of homelessness under the McKinney-Vento Act does not include those living in transitional housing not exclusively for the mentally ill, those who are in imminent threat of losing their housing, those fleeing a situation of domestic violence or other life-threatening condition, as well as unaccompanied youth and certain types of homeless families with children. Recent amendments to McKinney-Vento through the Homeless Emergency and Rapid Transition to Housing (HEARTH) Act will expand the definition of homelessness to include these families and individuals.16 Changes in the definition of who is counted as homeless were scheduled to go into effect in November, 2010. These changes, along with demographic changes in the nature of the military, particularly among those serving in the Operation Iraqi Freedom (OIF) and Operation Enduring Freedom (OEF) era, and as a result of the increase in women serving in the military, are likely to have an impact both on the numbers and needs of homeless Veterans and their families.16

## ASSESSING THE LIMITATIONS OF THE CURRENT RESEARCH

There are several limitations of the studies that have examined the individual level risk factors for homelessness.

### Problems in Sampling and Populations

Sampling limitations are common. Most studies include samples that disproportionately comprise the chronically homeless rather than the newly homeless. Studies often rely on small, geographically isolated samples, which make it difficult to make generalizations about the larger homeless population.17-19 In addition, several studies examine former homeless individuals, often termed “ever homeless,” in order to draw more generalizable conclusions about the homeless experience. Although such studies are useful, their sample selection includes only those, who for whatever reason, have made it out of homelessness, thus undersampling those who may have higher rates of symptom severity for risk factors such as substance abuse and mental illness.

Few studies directly assess the prevalence of psychiatric, substance abuse, or chronic illness in the general population of homeless Veterans. Most studies rely on already morbid populations seeking treatment for services and so cannot provide estimates of prevalence in the population as a whole. Fischer and Breakey20 further point out that much research has relied on nonrandom sampling frames, which may introduce bias, thus influencing prevalence rates of certain attributes. Rates of alcohol, drug, and mental health problems, for instance, tend to appear larger among homeless individuals sampled in shelters, clinics and on the streets; and lower in sampling sites such as food or service providers. 20

### Comparators

Few studies include appropriate housed control groups to determine the difference in prevalence for certain risk factors. Matched for race, gender, and age, census data or large household surveys give a sense of the differences in the homeless population as compared to the general housed population, but a more narrowly focused control group of marginally housed individuals living in poverty would present a more accurate picture of the predictive factors that are related to homelessness. Studies that include univariate comparisons often do so without calculating risk ratios.19-22

### Settings

Research on homelessness is often conducted in service settings, including shelters and rehabilitation centers, which increases the chance of over-representing the chronically homeless and under-representing those who are homeless for short periods of time. Because the chronic homeless tend to have higher rates of substance abuse and mental illness, an over-representation of the chronically homeless will result in an overestimation of such characteristics.23 Thus, choice of sampling site affects prevalence rates. 21

### Definitions

Existing studies also frequently differ in the definitions of key dependent variables, including homelessness itself. Some studies interpret homelessness as literal homelessness (sleeping in a shelter or on the street), while other studies include more liberal definitions. Some studies examine the dichotomy of ever/never being homeless, while others employ a strict point-in-time or cross-sectional definition and do not collect data on sample participants’ lifetime experience of homelessness.

### Measures and Measurement Issues

Measurements used to operationalize the included risk factors have not been consistent. For example, social support in some cases is measured as “having someone close to you that can provide support,” while other studies use marital status as a surrogate to determine the level of one’s social support status. Even questions regarding Veteran status can lead to different estimates. Asking, “Are you a Veteran?” for example, can generate a different response than asking, “Did you serve in the armed forces?” In addition, studies do not always include the same variables in their models. Several studies failed to include variables that have been found significant in other research, such as childhood adversity, employment history and former incarceration, and so may not adequately control for possible confounders. In addition, structural factors such as housing affordability or job market conditions have largely been left out of the research design in many of the studies examining risk factors for homelessness, although they have largely been significant in the models that have included them.22 Thus, it is impossible to determine if controlling for structural risk factors would have altered the results of such research.

In addition to the methodological inconsistencies described above, we found great variability in the methods and instruments used to determine the prevalence of alcohol abuse, substance abuse, and mental illness among homeless Veterans. The type of measurement used (current use, past use, or lifetime use) is also largely inconsistent. We found that a large percentage of studies have based their findings on self-report (which depends greatly on the willingness of self-disclosure of study participants) or on instruments in which there is no clear evidence of validation for the homeless population. Differences in prevalence between studies using self-report vs. standard instruments can be stark. Fischer and Breakey point out, moreover, that estimates based on prior treatment history may not be accurate because of the various ways in which individuals seek help from service providers. Some patients, for example, seek help through outpatient services and, so, would not be included in counts of hospitalized patients – a common measurement threshold for prevalence estimates of mental illness and substance abuse.20

Much of the research that examines the associations between substance abuse/mental illness and homelessness does so from a pathology perspective rather than from an adaptation perspective.24 By using instruments that are designed primarily for use on clinical populations, such research may misinterpret adaptive behaviors as pathology. We suggest that researchers should provide evidence of validation for the instruments used when reporting the associations between substance abuse and/or mental illness among homeless Veterans. By addressing the validation of instruments used on the homeless population, researchers will be able to draw a more accurate picture of the risk factors associated with homelessness among Veterans.

### Study Design

Many of the studies examining Veteran homelessness employ a cross-sectional research design, which limits the interpretation of cause and effect regarding substance abuse/mental illness and homelessness. Thus, in many cases, it is unclear as to whether substance abuse and/or mental illness preceded homelessness, or if substance abuse and/or mental illness are the result of adaptations to the stresses and dangers associated with the homeless experience.

### Summary of Limitations

Because of the inconsistencies in the instruments used and the inherent differences found in study design, comparisons across studies are problematic. We agree with Fischer and Breakey that comparisons of studies should take into account differences in problem definition, method of assessment, sampling techniques, and demographic characteristics of the sample.20

## DATA SOURCES

A recent Government Accounting Office (GAO) review of Federal data and other studies on homelessness concluded that “these data have a number of shortcomings and consequently do not capture the true extent and nature of homelessness.”25 While that review was broadly focused on data on homeless populations in general, it did include a review of data available on homeless Veterans, and many of its findings are equally applicable to data on the Veteran sub-population.

### Annual Homeless Assessment Report (AHAR) and Community Homelessness Assessment, Local Education, and Networking Group (CHALENG) Report Data

There are three current data sources widely relied on for estimating the number of homeless Veterans:

- The AHAR provides estimates of Veteran homelessness from two data sources:
  ○ the Department of Housing and Urban Development’s (HUD’s) Point-in-Time (PIT) estimate, that gives an approximation of the number of homeless individuals and families during a single night in January;
  ○ the Homeless Management Information System (HMIS) estimates, which produce counts of the sheltered homeless population during a calendar year; and
- The annual CHALENG for Veterans report uses a combination of data sources to determine a count of Veteran homelessness.

PIT estimates are gathered on a single night during the last week in January. Continuum of Care (CoC) applications are submitted to HUD annually as part of the competitive funding process and provide one-night, PIT estimates of both sheltered and unsheltered homeless populations. 14 Information about homeless subgroups are also collected.

HMIS are electronic administrative databases that are designed to record and store client-level information on the characteristics and service needs of homeless persons. HMIS data are used to produce counts of the sheltered homeless population over a full year. It includes people who used emergency shelter or transitional housing programs at some time during the course of a year. 14

Since 1994, the VA has estimated the number of Veterans receiving services in its CHALENG program. Estimates are derived through partnerships with representatives from each local VA medical center (VAMC) and service providers from state and local governments and nonprofit organizations. Using a point-in-time estimate, each VAMC estimates the greatest number of Veterans who are homeless on any given day in the previous fiscal year. Various sources are used to arrive at the estimates and include HUD PIT counts, previous Census estimates, VA client data, VA staff impressions, or combinations of sources. 26

Estimates from the most recent CHALENG report are based on PIT estimates of the number of Veterans homeless on any day during the last week of January 2008. While these estimates include both sheltered and unsheltered Veterans, like all PIT estimates, the CHALENG count is likely to undercount those who are not chronically homeless. In addition, these estimates are often adjusted to better align with estimates based on the HUD PIT count, noting that “CHALENG has increasingly relied upon HUD PIT counts as the basis of its own estimate.”26 The reasons for this are unclear. This approach establishes the HUD count as a gold standard despite the CHALENG authors’ own acknowledgment that the HUD PIT counts may not have included areas with concentrations of homeless Veterans known by those responsible for the CHALENG estimate.26

HUD and the VA have recently collaborated in producing and releasing a Veteran-specific supplement to the annual AHAR. This report Veteran Homelessness: A Supplemental Report to the 2009 Annual Homeless Assessment Report to Congress27 (2009 Veteran AHAR) is a major contribution to our understanding of the extent and nature of homelessness among Veterans. The report is based on PIT and HMIS data collected as described above using a standard, validated method to minimize potential duplication in the count, and with statistical adjustments made to account for undercounting. The 2009 Veteran AHAR provides national one-day and one-year estimates of homeless Veterans and describes their demographic characteristics and patterns of shelter use. We recommend that the Veteran AHAR be used as the most comprehensive and reliable source of information on the prevalence of homelessness among Veterans currently available. The report is available at: http://www.hudhre.info/documents/2009AHARVeteransReport.pdf.

Our report should be seen as a complementary report that provides a critical review of the research and literature on homelessness among Veterans.

In addition to the AHAR and CHALENG counts, which attempt to provide national estimates of the number of homeless Veterans, other data sources are used to provide estimates of subpopulations of homeless Veterans and their individual characteristics, and to identify risk factors for homelessness among Veterans. What follows is an overview of some of the more central of those data sources. This is not intended to be a comprehensive review of all data sources on homeless Veterans; rather, it is a review of what we consider to have been a core set of those data sources – those that have been consistently used in a number of studies, and those which we consider exemplars of the strengths and weaknesses of data on homeless Veterans.

### National Vietnam Veterans Readjustment Study (NVVRS)

One of the earliest sources of data on Veteran homelessness and on related factors such as drug and alcohol use and post-traumatic stress disorder (PTSD) was the NVVRS. Conducted between September 1984 and November 1988, this study of 1,200 Veterans provided a representative sample of all persons on active duty in the U.S. military during the Vietnam War era (August 5, 1964 through May 7, 1975).

Although it was a well-conducted study, the population may not be representative of post-Vietnam era Veterans. Theater Veterans of the Vietnam War era were younger and less likely to be female or minorities than subsequent Veteran cohorts. They also served during a period of a military draft – while Veterans of the post-Vietnam era served in an all volunteer military, over 40 percent of the respondents to the NVVRS had been drafted or enlisted to avoid the draft. While in 1974, 60 percent of the active duty force were age 25 or younger, by 2000, that percentage had declined to 46 percent; and while in 1974, only 3 percent of the active duty force were women and 20 percent were minorities, by 2000, women accounted for 15 percent and minorities 35 percent of those on active duty.28 Since the Vietnam era, the military has also seen an increase in service members with family obligations. 29

Two current studies, the Health of Vietnam Era Veteran Women’s Study (Health VIEWS)30 and the Millennium Cohort Study (MCS),31 may provide additional information on the prevalence of risk factors for homelessness among women Veterans (Health VIEWS) and among OEF-OIF Veterans (MCS).

### National Survey of Homeless Assistance Providers and Clients (NSHAPC)

One of the most widely used sources of information on homelessness in general, as well as on homelessness among Veterans, is the NSHAPC. This survey was conducted between October 18, 1996 and November 14, 1996 and included a nationally representative sample of over 4,000 homeless clients of nearly 12,000 homeless assistance providers. The survey collected data on, among other things, Veteran status, mental health, drug and alcohol use, and homelessness status (currently or formerly). While in 1996, 13 percent of adult U.S. population were Veterans, 23 percent of the then currently homeless clients were Veterans. Considering males only, 33 percent of the male homeless clients were Veterans compared with 31 percent of the adult male U.S. population.

While a number of later studies of homelessness among Veterans made use of the NSHAPC data, several limitations to the data should be noted. First, the study includes information only on clients of services for the homeless and does not include information on the homeless who did not access services. It also entirely excludes the homeless in communities that had few or no homeless assistance programs. In addition, all client data, including data on physical and mental health problems, use of alcohol and drugs, and incarceration were based on self-report. Finally, because the survey collected data on homelessness was only for the period of one month, as with all point-in-time surveys, it will likely reflect a bias towards those who are chronically as opposed to episodically or temporarily homeless.

### Health Care for Homeless Veterans (HCHV)

Many of the studies of homelessness among Veterans are based on data from clinical populations receiving services in VA programs, and so may have limited applicability to an understanding of homelessness among Veterans more generally. While these are often large national data sets, they nevertheless capture data only on those Veterans participating in those programs. In addition, these programs are often focused on Veterans with particularly acute service needs. A description of some of the programs most frequently used as sources of data follows.

#### Homeless Chronically Mentally III Veterans Program (HCMI)

The HCMI program was established in 1987 at 43 Veteran Administration Medical Centers in 26 states and the District of Columbia as a program for Veterans with psychiatric problems. An initial assessment of the program conducted between May 1987 and March 1988 found that the median age of participants was 40 (younger than Veterans in the general population); that 67 percent needed specialized psychiatric, and 72 percent needed medical evaluation or treatment: that 46 percent reported significant substance abuse and 65 percent reported a previous hospitalization for either a psychiatric or substance abuse problem; that 47 percent were living in shelters, 9 percent were doubling up, 8 percent had a room or apartment, and 35 percent had no residence; and that over half were Vietnam era Veterans.

#### Domiciliary Care for Homeless Veterans (DCHV)

The DCHV program was also established in 1987 as a 20-site expansion of the VA’s existing domiciliary care program. It was targeted at Veterans who were either medically or psychiatrically disabled, and who were either homeless or at imminent risk for homelessness. In an initial assessment of the program conducted between November 1987 and November 1988, nearly 90 percent of admitted Veterans received major psychiatric or substance abuse diagnoses; 69 percent had been hospitalized at a VAMC for a substance abuse, psychiatric, or medical problem in the previous year; 47 percent had a current substance abuse problem, 36 percent a current psychiatric problem, and 16 percent were dual diagnosed; and 54 percent had a serious chronic, medical illness.

#### Access to Community Care and Effective Service Supports (ACCESS)

The ACCESS program was established by Substance Abuse and Mental Health Services Administration (SAMHSA) in 1993 as a five-year demonstration project to identify effective approaches to providing services to homeless persons with serious mental illnesses. Clients were eligible for case management services if they were homeless, suffered from severe mental illness, and were not involved in ongoing treatment in the community. Of those who eventually enrolled in the case management phase of the program, 67 percent were diagnosed with a psychotic disorder (37 percent with schizophrenia, 32 percent with other psychoses, 20 percent with bipolar disorder), 49 percent were diagnosed with major depression, 22 percent with personality disorder, and/or 19 percent with anxiety disorder (diagnoses are not mutually exclusive); 43 percent were diagnosed with alcohol abuse; and 38 percent were diagnosed with drug abuse.

## METHODOLOGICAL CONSIDERATIONS

Estimates of the number of homeless are sensitive both to the definitions of homelessness (who is deemed homeless) and the methods for counting the homeless population.21, 23 Point-in-time estimates are more likely to capture the chronically homeless population than HMIS counts, and may undercount those who are transitionally or episodically homeless. The HMIS counts, however, are sensitive to under-reporting, since CoCs are not required to submit HMIS data. The Veteran AHAR statistically adjusts the raw count to account for undercounting in the PIT estimate of one-day sheltered and unsheltered homelessness, and uses statistical adjustments and weighting of the HMIS to produce national one-year estimates of the sheltered homeless.27 The accuracy of those estimates will be sensitive to the validity of the assumptions underlying the adjustments. Appendix A of the Veteran AHAR provides a description of the methodology used to adjust the PIT counts,27 and Appendix B.5 of the 2009 AHAR provides a description of the methods used to adjust and weight the HMIS estimate.14

There are several data collection issues that make estimating the number of homeless Veterans difficult. Those who are doubled up with family or friends but who would otherwise be without shelter are generally not included in homeless samples.32 Estimates of Veteran homelessness often will miss the hidden homeless who sleep in automobiles, in campgrounds or in other areas not easily identified by researchers, as well as those who may intentionally hide from researchers. 32

## KEY QUESTION #1A What is the prevalence and incidence of homelessness among Veterans?

For reasons discussed earlier in the Limitations section, the exact number of homeless Veterans is unknown. The most recent CHALENG for Veterans report estimates that on on a single night in January 2008 there were 107,000 homeless Veterans.26 This represents a decrease of 18 percent from the estimate of 131,000 homeless Veterans reported in the 2008 CHALENG report.26 It is argued that this is primarily the result of changes in counting methods rather than an actual decline in the number of homeless Veterans.33 The CHALENG report further speculates that improved methods (such as adjusting estimates to better coincide with local HUD PIT counts), VA program interventions, changing demographics, and recent events (i.e., reduction in estimates due to ongoing recovery from the effects of Hurricane Katrina) may have had an impact on the reported prevalence of homelessness among Veterans.26 With nearly 23 million Veterans in the U.S. population in 2008, and an estimated 107,000 homeless, the rate of homelessness among Veterans was approximately 47 for every 10,000 Veterans. This rate is more than double the rate of homelessness in the general adult population. 14

The recently released 2009 Veteran AHAR estimates that on a single night in January 2009 there were 75,609 homeless Veterans and that an estimated 136,334 Veterans spent at least one night in an emergency shelter or transitional housing program between October 1, 2008 and September 30, 2009.^27^ Based on the Veteran AHAR estimate of 75,609 homeless Veterans on a single night in January 2009, approximately 33 of every 10,000 Veterans were homeless.

In 2009, Veterans made up just under 10 percent of the U.S. adult population, and over 11 percent of the adults in emergency shelters or transitional housing between October 1, 2008 and September 30, 2009. This accounts for 1 of every 168 Veterans in the U.S. or 1 in every 10 Veterans living in poverty. 27 In addition, it has been argued that from 89,553 to 467,877 Veterans are at risk for homelessness.33 In the United States, men in general are more likely to be homeless than women, and the Veteran population continues to be disproportionately male, so some of this increased risk can be ascribed to this. However, while females comprise only 6.8 percent of the total Veteran population, they made up 7.5 percent of homeless Veterans. 27

While Blacks make up only 11 percent of the overall Veteran population, they were 34 percent of the homeless Veterans. Similarly, Hispanics comprise only 5 percent of all Veterans, but 11 percent of homeless Veterans; and American Indian and Alaska Natives, while comprising less 1 percent of all Veterans, were over 3 percent of the homeless Veterans. 27

In 2009, nearly half of all Veterans were between the ages of 31 and 50, and over a third were between 51 and 61. Over 11,000 Veterans between the ages of 18 and 30 used an emergency shelter or transitional housing in 2009, suggesting a potential growing need to address the problem of homelessness among Veterans of Operation Iraqi Freedom and Operation Enduring Freedom. 27

## KEY QUESTION #1B How has the prevalence and incidence of homelessness among Veterans changed over time?

Because of changes in reporting and in the methods for counting the number of homeless, estimates of the prevalence of homelessness among Veterans over time are not comparable. The 16^th^ CHALENG report estimated that there were 107,000 Veterans homeless on a single day in January 2008.^26^ In contrast, the 2009 Veteran AHAR estimates that there were 75,609 homeless Veterans on a single night in January 2009.^27^ While this 30 percent decrease in the number of homeless could be real, it is more likely an artifact of changes in the methods for counting and adjusting estimates; therefore, we suggest caution when using previous estimates to examine changes in prevalence over time. HUD and the VA intend to continue to collaborate on future annual Veteran supplements to the AHAR which should result in more consistent estimates for tracking trends in homelessness among Veterans.

However, even these new estimates should be interpreted with caution for several reasons. First, as HUD points out, the HMIS data on Veteran status are for sheltered homeless only. Some researchers have speculated that Veterans, are more likely than other homeless groups to remain unsheltered.14 Second, some of the residential programs for the homeless that are funded through the U.S. Department of Veterans Affairs do not report data to the CoC. Moreover, there is anecdotal evidence that homeless Veterans do not always reveal their Veteran status to program staff.14

It has been speculated that the number of homeless Veterans will increase, as Veterans return from OEF and OIF suffer from high rates of mental illness and traumatic brain injury; these and other returning Veterans may experience problems in obtaining employment within the civil sector.34 The accuracy of these speculations may not be known for many years, as historically Veteran homelessness usually occurs long after return to civilian life. In a study of over 1,400 homeless males, 76 percent of combat Veterans and half of all noncombat Veterans first became homeless more than a decade after leaving military service.35 In addition, the demographic composition of the Veteran homeless population is changing. As documented by Kuhn et al. (2010), VA facilities recently reported an increase of 24 percent in homeless Veteran families seeking services from those facilities. Indeed, family issues such as child care were among the top 10 needs reported by homeless individuals in the most recent CHALENG survey.26 A recent study assessing risk factors for homelessness among female Veterans found that 16 percent of homeless Veterans had children under the age of 18 living with them during the prior 12 months.36 The percentage of homeless women Veterans is expected to increase as the percentage of female Veterans has increased dramatically in recent years. Over 165,000 female troops have been deployed to Iraq and Afghanistan, a much higher number than deployed during the Vietnam and Gulf Wars.16 Researchers should remain alert to the possibility that changing demographics within the military may, in the future, be associated with different, potentially more rapid paths to homelessness.

## KEY QUESTION #1C How prevalent are psychiatric illness, substance abuse, and chronic medical illness among homeless Veterans?

There are few studies directly assessing the prevalence of psychiatric, substance abuse, or chronic illness in the general population of homeless Veterans. Most studies rely on already morbid populations seeking treatment for services and so cannot provide estimates of prevalence in the population as a whole. Of the studies we located which focus on substance abuse and mental illness among homeless Veterans, we found very little consistency in the methods and instruments used to determine the prevalence of substance abuse and mental illness. The type of measurement (current use, past use, and lifetime use) was also inconsistent, which can greatly affect reported prevalence rates, as those reporting lifetime drug abuse or mental illness will have higher rates compared with those reporting current abuse or illness. It is also difficult to determine from the included studies if distinctions were made between hazardous use, abuse, and dependence. The severity of abuse has implications for functioning, risk, and capacity to engage in services.

Several studies have based their findings on self-report, a method which depends greatly on the willingness and accuracy of self-disclosure of study participants, or on instruments for which it is unclear if they have been validated with homeless populations. Differences in prevalence between studies using self-report vs. those using standard instruments can be substantial. Fischer and Breakey20 point out, moreover, that estimates based on prior treatment history may not be accurate because of the various ways in which individuals seek help from service providers. Some patients, for example, seek help through outpatient services and thus would not be included in counts of hospitalized patients – a common measurement threshold for prevalence estimates of mental illness and substance abuse. Because of these inconsistencies, comparisons across studies are problematic.

Furthermore, many of the studies examining Veteran homelessness employed a cross-sectional research design, which limits the interpretation of cause and effect regarding substance abuse/ mental illness and homelessness. Nevertheless, we feel that the evidence is adequate and consistent enough with evidence regarding the prevalence of these conditions in homeless populations in general,21, 22, 37 to state that the prevalence of mental health, substance abuse, and medical problems among Veteran homeless is high, despite access to Veteran Health Administration (VHA) services.

Existing evidence suggests that homeless Veterans have higher rates of substance abuse (drug and alcohol abuse), mental illness, and chronic illness when compared to housed Veterans. However, here, too, estimates vary. A study based on a convenience sample of homeless adults admitted to homeless shelters in Santa Clara County, California between November 1989 and March 1990 found that 17 percent of Veterans had been admitted for overnight treatment of psychiatric problems, 29 percent reported actual and 39 percent perceived alcohol abuse, and 22 percent reported illegal drug use.35 More recently, in a cross-sectional, community-based survey of homeless male Veterans (N=127) and non-Veterans (N=298) in Pittsburgh and Philadelphia during a five-month period in 1997, O’Toole et al. 37 sampled from emergency shelters, transitional and supportive housing units, and soup kitchens or drop-in sites to ensure adequate representation of all homeless persons. That study found that 61.4 percent of homeless Veterans reported psychiatric problems, 79.5 percent reported alcohol or drug abuse or dependence, and 66.1 percent reported having at least one chronic medical condition. 37 In addition, Veterans were more likely to report a chronic medical condition than non-Veterans (66% vs. 55%, p = 0.04). Of the 127 male Veterans included in the study, 24 percent reported hypertension, 19 percent hepatitis/cirrhosis, and 7 percent each diabetes and heart disease, while 36 percent reported two or more chronic conditions. Of note, the usual sources of care for the Veteran population were shelter-based clinics (48 percent) as opposed to community clinics (35 percent). As a whole, homeless Veterans have higher rates of chronic illness compared to homeless non-Veterans, but tend to have similar rates of substance abuse (alcohol or drug abuse) and mental illness when compared to their non-Veteran counterparts, although Veterans tend to have better access to care.37

A study of homeless Veterans with physical, mental, and substance abuse disorders seeking treatment from the DCHV Program examined indicators for chronic homelessness. The study consisted of two samples, with both samples including short-term (<12 months since age 18) and chronic (>12 months since age 18) homeless Veterans. The study found chronic homelessness to be associated with substance abuse disorders for both samples, but only one sample showed an association between mental illness (depression and anxiety) and chronic homelessness.38

In a secondary analysis of national VAMCs’ administrative data on over 40,000 housed and homeless patients receiving inpatient care between 1996 and 1998, Adams et al.39 found that a significantly greater proportion of homeless patients than housed had a psychiatric disorder (42.1% vs. 22.1%, p <= 0.001) or substance abuse (37.7% vs. 6.9%, p <= 0.001) as a discharge diagnosis. Homeless persons in this study included both the literal homeless and those doubled up, i.e. staying temporarily with family or friends. No major differences were found between housed and homeless Veterans regarding surgical or medical conditions.

## KEY QUESTION #2A Which risk factors are associated with new homelessness or a return to homelessness among Veterans? How do these risk factors differ from non-Veteran populations?

Risk factors most strongly and consistently associated with homelessness include childhood risk factors such as inadequate care by the parents, experiencing foster care or group placement, and prolonged periods of running away from home. These risk factors have also been consistently found to be associated with homelessness in the general population.21, 40, 41 Overall, homeless Veterans and non-Veterans tend to have similar rates of alcohol and substance abuse.35, 37 Comparisons of rates of mental illness and overall health status between Veterans and non-Veterans have not found a consistent association across studies.35, 42

There do not appear to be differences between Veterans and non-Veterans with regard to some of the factors most immediately associated with homelessness. However, there do appear to be unique, military-related pathways by which Veterans are exposed to these factors, since Veteran-specific exposures such as combat injury, intense or prolonged combat, and Military Sexual Trauma all have an impact on shared exposures such as mental illness and low or unstable income.

There are notable differences in the prevalence of some characteristics often found to be protective. Veteran homeless tend to be older and better educated, have had better early family cohesion, and are more likely to be or have been married than non-Veteran homeless. The reasons for the absence of expected protections are not well understood. It may be that the differences between these populations are too small to influence outcomes significantly. Alternatively, there may be unique Veteran experiences associated with either service or post-deployment readjustment that actively undermine the protective mechanism associated with these factors in other populations. For example, it may be that individuals with strong positive family experiences or high social support in the form of marriage may actually be more negatively affected by the physical and emotional dislocation of combat service than those who have weaker social support networks. Similar arguments have been offered to explain why National Guard Veterans, who are often older, more established in their civilian lives, and less connected to the social supports and services offered to active military post-deployment, are often considered, at least anecdotally, to have particularly severe post-deployment readjustment difficulties.43 Research is needed to move these explanations beyond mere conjecture, however.

## KEY QUESTION #2B Have risk factors for homelessness among Veterans changed over time?

We found no evidence to suggest that risk factors themselves change over time. What the evidence does show is that over time, certain risk factors become more salient than others and that they affect different sub-populations. Military-related trauma, for instance, has always been a risk factor for the subsequent development of mental illness putting one at risk for homelessness. Historically, the trauma most closely associated with military service has been PTSD, but with the increasing number of women in the military, military sexual trauma (MST) has become an important and prevalent additional trauma-associated risk factor. Similar comments can be made regarding the increasing number of family-involved Veterans. The wars in Iraq and Afghanistan have led to an increase in the number of National Guard Veterans serving often repeated tours of duty in these conflicts. Since these Veterans are more likely to have families during and immediately after deployment, the importance of factors related to homelessness among families has increased. Similarly, if certain aspects of combat experience put Veterans at increased for homelessness – something which the evidence suggests – these will only be relevant risk factors during periods when U.S. forces are engaged in combat missions. Finally, economic and structural factors will strongly influence who is at risk. In good economic times, those most vulnerable because of personal risk factors will become homeless; as economic conditions worsen, an increasing number of those less vulnerable will also become homeless.

## KEY QUESTION #3 Are there factors specific to military service that increase the risk of homelessness, or is the increased risk a marker for pre-military comorbidities and social support deficiencies?

Very little research designed to investigate military specific risk factors for homelessness has been conducted. Pre-military risk factors or comorbidities do not account for the over-representation of Veterans among the nation’s homeless. Prolonged or intense combat exposure appears to indirectly increase the risk of homelessness through its impact on mental health, employment, and social support.15, 44-51 Some exposures that may increase the risk of homelessness, like alcohol/drug abuse and low social support, frequently emerge during service or the post-deployment period.52, 53 Though only examined to date by one small study, MST has been associated with increased risk of homelessness among female Veterans. 36

No study has comprehensively looked at risk factors for emerging OEF/OIF cohorts of Veterans. Future research should employ longitudinal study designs and more detailed data concerning combat exposures to track the general population of Veterans’ exposures to clearly-defined potential risk factors during active duty and the readjustment/post-deployment period.

### Pre-military Risk Factors or Comorbidities Do Not Account for the Over-representation of Veterans among the Nation’s Homeless

Some studies have found that homeless Veterans have lower prevalence of some general population risk factors (such as family dysfunction) and higher prevalence of protective factors (such as higher educational levels) when compared with other homeless individuals.36, 54, 55 These findings suggest that pre-military risk factors or comorbidities do not account for the over-representation of Veterans among the nation’s homeless. As has been found for the general population, some childhood risk factors are strongly associated with Veteran homelessness,15 but the limited evidence available suggests that these risk factors are no more prevalent among Veterans than among the general population. Veterans as a group appear to actually be at decreased risk for some exposures associated with homelessness in the general population.

In bivariate analysis, Rosenheck and Fontana (1994)15 found an increased risk ratio for homelessness for those who had been in foster care, but only 0.7 percent of their sample had experienced such care. Their structural equation model also found that childhood abuse, childhood trauma and psychiatric treatment before age 18 were all significantly associated with homelessness, but they did not report how the prevalence of these exposures compared with prevalence in the general homeless population.15 Tessler, Rosenheck and Gamache55 found that while pre-military misconduct and childhood family instability were both significantly more prevalent among younger cohorts of homeless Veterans compared to older cohorts, overall, Veterans were significantly less likely than the general homeless sample to have experienced either exposure.

In terms of protective factors, Tessler, Rosenheck and Gamache found that homeless Veterans were likely to be slightly (on average < 1 year) more educated than homeless non-Veterans,55 a finding similar to that of Rosenheck and Koegel’s earlier study.42 This is consistent with the finding that education may be protective against homelessness within Veteran populations, as was found by Washington, Yano and McGuire’s36 small single-site study comparing currently housed and non-housed female Veterans.

Studies examining whether Veterans as a group possess better social support than the general population have produced mixed results, which is likely due, in part, to poor consensus on how to define and measure social support. Marital status is the most common measure of social support, and findings with regard to marriage suggest that homeless Veterans are more likely than homeless non-Veterans to have ever been married.42, 55 More centrally, the validity of marriage as a useful measure of social support has been questioned; more nuanced and better validated measures such as the Medical Outcomes Study (MOS) Social Support Survey 56 or Lin’s Strong Ties Measure57 would strengthen any findings regarding this risk factor. The NVVRS employed a richer definition of social support, but its findings did not report differences in pre-military social support between overall Veteran and comparison general population.

Rosenheck and Koegel42 used data from three surveys of homeless service users in 1986-1987 to investigate differences between Veteran and non-Veteran homeless men, and found no significant differences in risk factors associated with physical or psychiatric illness; homeless Veterans were more likely to have been treated in the past for alcohol problems, but the authors suggest that this is likely an artifact of greater access to care through VA services. Though these findings are now dated and ideally should be tested against findings from a more current sample, there is to date no study to contradict Rosenheck and Koegel’s conclusion that “veterans appear to be at risk for homelessness for much the same reasons as other American men.”42

While Veterans thus appear to be at risk for homelessness for much the same structural reasons as other Americans, there are qualitative differences in their pathways of exposure which warrant further research. The influence of unique exposures (such as combat exposure or MST) on more proximate, shared exposures (such as poor mental health) requires research designed specifically to investigate this topic further.

### Prolonged or Intense Combat Exposure Indirectly but Substantially Increases the Risk of Homelessness

Two studies that investigated homelessness outcomes in relation to exposures to hypothesized military service risk factors were identified: Rosenheck and Fontana15 and Washington, Yano and Macguire.36 Rosenheck and Fontana looked at pre-service, military service (combat exposure and participation in atrocities), and post-service experiences as risk factors for Veterans serving during the Vietnam War era; Washington and colleagues examined military and other sexual trauma among female Veterans of several eras. Rosenheck and Fontana’s data allowed for a division of the sample into ever-homeless and never-homeless, while Washington and colleagues did not collect data on past housing status and, in fact, noted in their results that much of their housed population might be at risk for homelessness due to common characteristics. This difference in how “homelessness” was defined may account for some of the differences in their findings, as may the fact that Rosenheck and Fontana’s study included only men and was conducted nearly two decades before Washington and colleagues’ study, which included only women. Both studies were observational, cross-sectional studies which could not examine causality, although Rosenheck and Fontana’s structural equation model allowed for modeling of temporal relationships among some variables. A longitudinal study collecting baseline data prior to military service and tracking individuals through time to determine ever/never homeless outcomes would contribute greatly to the evidence base in this area.

No study identified in our review found a direct significant association between prolonged/ intense combat exposure and homelessness. The definition of prolonged or intense combat exposure has varied, which increases the difficulty in evaluating existing evidence. The NVVRS examined both intensity and duration of combat.44 It also found an association between PTSD and lower military pay-grade, which Seal49 used as part of a proxy definition for combat exposure (along with branch of service and single vs. repeat deployment). Rosenheck and Fontana15 found no direct association between homelessness and intense combat exposure, but they found direct effects of combat exposure on non-PTSD psychiatric illness (schizophrenia was not assessed), substance abuse, not being married, and low social support after discharge, all of which were associated with homelessness. They did find a weak association between homelessness and “participation in wartime atrocities,”15 a uniquely regrettable military exposure; this measure has not been replicated by other studies. Research primarily comparing Vietnam-era and post-Vietnam era Veterans has found that Veterans most at risk for homelessness are in the age cohorts least likely to have served in combat.58 Long-term, longitudinal research involving Veterans from OIF and OEF should be undertaken to reassess the role of combat and its associated risk for homelessness. The recent development of the Deployment Risk and Resilience Inventory (DRRI)59 provides a multi-scale inventory capable of capturing data on more nuanced aspects of combat experience and associated stress, and which has been validated for use with OIF Veterans. Future research should consider the use of this inventory.

As previously mentioned, however, risk factors for homelessness rarely occur in isolation. For this reason, the conceptual attempt to understand Veteran homelessness requires acknowledgement of synergistic effects that may occur after exposure to multiple direct or indirect risk factors.

#### Combat’s Impact on Mental Health

Clearly, not all mental health problems experienced by Veterans are related to their military service. Despite pre-service screening, some military service members will enter the military with mental health problems that may or may not be known at the time. As already discussed, childhood trauma, which frequently leads to mental health problems, has been shown to increase the risk of homelessness in both Veteran and general populations. Similarly, Rosenheck and Fontana’s15 finding that psychiatric treatment of any kind before the age of 18 increased the risk of homelessness among the 0.7 percent of Veterans in their sample receiving such treatment suggests that, for the small population affected, pre-existing mental health problems are likely to exert a significant and diverse influence on their well-being. Our focus here, however, is on mental illness that is more directly linked to military service, the best-studied example of which is combat-related PTSD. Estimates of lifetime PTSD expression within Veteran populations vary, but one recent national study of OEF/OIF Veterans entering VA care found a prevalence of 21.8 percent for PTSD, a notable portion of the 42.7 percent with any mental health diagnosis.49

PTSD, it should be noted, is more prevalent in the general population than is often assumed, and as one study60 of incarcerated Veterans found, combat exposure may not be the type of trauma most strongly associated with developing PTSD, even among Veterans. As the literature on PTSD expands, there is an increasing acceptance that, at least in some cases, psychosocial context – the daily stresses individuals encounter – may be as important to the expression of PTSD symptoms as the severity of the original trauma.61 Keeping these caveats in mind, several studies have consistently found an association between prolonged or intense combat exposure and an increased risk of a PTSD diagnosis, PTSD symptoms, and/or anxiety or depression, even when controlling for predisposing factors. The NVVRS report44 as well as Rosenheck and Fontana’s study based on the same data set15 both found PTSD more prevalent among those who had served longer tours of duty and who reported higher “war zone stress” as measured by a variety of traumatic exposures. An association between combat exposure and PTSD has also been found by a longitudinal study that looked at twin pairs with discordant Vietnam theater/ era service,45, 46 as well as cross-sectional studies of mixed Veteran cohorts receiving VA primary care47, active duty and reserve Iraq Veterans48, 49 and combined Iraq/Afghanistan National Guard Veterans returning for a repeat deployment.50

However, the evidence linking PTSD to homelessness remains limited by the small number, small size and/or non-generalizable sampling methods of existing studies. Positive PTSD screening was found to be associated with homelessness by Washington, Yano and McGuire36 but not by Rosenheck and Fontana,15 where the authors concluded that PTSD’s effect was likely to be accounted for by other psychiatric disorders with which it shared variance.15 In general, analysis of the association between mental illness and Veteran homelessness is limited by the inconsistency of mental health conditions assessed across and within studies. For example, Washington, Yano and McGuire36 found an association between positive PTSD/anxiety disorder screening and homelessness, but not positive depression screening or problem alcohol use, and schizophrenia was not assessed. The NVVRS did not assess participants for schizophrenia, a condition associated with homelessness in the general population.15 Perhaps not surprisingly, given that the study’s sample was of men seeking care for mental health issues, Tessler, Rosenhack and Gamache55 did not find any significant difference between the Addiction Severity Index (ASI)-Psychiatric scores of Veteran and non-Veteran homeless men.

As several authors of the studies reviewed noted, the existential challenges of life as a homeless person are likely to negatively impact an individual’s mental health, so cross-sectional studies of the prevalence of mental illnesses among the homeless are unlikely to provide definitive evidence on the extent to which mental illness affects one’s risk for homelessness. There is consistent evidence from research on the general homeless population that indicates mental illness (schizophrenia, bipolar disorder, and depression) is associated with homelessness, including the duration of homelessness.19, 62-64 There is some disagreement, however, as to whether mental illness itself increases the risk of homelessness.65

#### Combat’s Impact on Income and Employment

While an association between unstable employment and/or low income and homelessness seems intuitive, few studies have examined the strength of these associations within Veteran homeless populations. Washington, Yano and McGuire36 found that among female Veterans, homelessness was associated with being unemployed and being disabled. Rosenheck and Fontana15 did not include NVVRS data on post-deployment employment, disability, or income in their analysis and so could draw no conclusions.

In a study analyzing data from multiple waves of the Panel Study of Income Dynamics between 1968 and 2003, MacLean51 found that combat exposure (not further defined by intensity or duration) increased the rates of disability and unemployment among Veterans compared to non-combat Veterans, both in their early working years and throughout life. MacLean’s analysis suggested a direct cumulative disadvantage effect that negatively affected combat Veterans regardless of pre-military service characteristics such as education. In contrast, Resnick and Rosenheck’s66 study of 5,862 male Veterans participating in a vocational rehabilitation program, the majority of whom reported being homeless, found that service in a theater of operations was associated with better chances of employment at program discharge. However, Veterans with PTSD or other severe mental illness were found to have less successful employment outcomes (fewer days worked), a finding consistent with other studies which have found negative correlations between severity of PTSD symptoms and wage levels/full-time employment44, 47, 67, 68 and between PTSD diagnosis and stability of employment.44

#### Combat’s Impact on Social Support

As among the general homeless population, low social support, though inconsistently defined, has been associated with Veteran homelessness. Rosenheck and Fontana15 found that low social support in the year after discharge from the military had the strongest direct effect on homelessness risk. In bivariate analysis, the separate measure of not being married was also associated with an increased risk of homelessness, although the study design could not investigate whether homelessness preceded or followed not being (currently) married. Washington, Yano and McGuire36 found that among female Veterans, marriage (a narrow but common measure of social support) was protective against homelessness.

Social support is a complex construct, and there is considerable academic discussion about the mechanisms through which social support actually makes a difference in people’s lives, and what kinds of support matter most. Social support is by its nature located both within the individual’s personal relationships (who may be married, have strong family ties, etc.) and the society around him or her (which may provide more institutional avenues for social support); when it is extended to consider one’s relational position within society, and the opportunities for more institutional support, this is often conceptualized as social capital.69, 70 All of the Veteran specific research studies identified defined social support predominantly in terms of individual relationships, with less attention paid to social capital/social support at the level of social institutions. None of the studies reviewed specifically investigated what type of social capital is most likely to provide support for homeless Veterans to move out of homelessness.

The only study identified which directly assessed associations between combat exposure and social support was the NVVRS,44 which found an association between high war-zone stress (intense combat exposure) and poor family functioning, as well as more frequent divorce or marital problems. Several Department of Defense and other government agency reports have expressed concern at the impact that repeat or lengthy deployments may be having on the mental health of OEF/OIF troops,71, 72 but this concern has been poorly translated into research on the psychosocial difficulties of post-deployment life. Some of the findings from the studies reviewed suggest that poor social support may also be associated with worse employment outcomes,66 though the direction of the relationship is not clear. PTSD remains better researched than (re) adjustment disorders or employment difficulties, so the literature on PTSD provides the best source of data on combat’s influence on social support.

Prolonged combat exposure increases the risk of developing PTSD, which the NVVRS found to be associated with extreme isolation and extreme unhappiness.44 More recent studies have found an association between PTSD and poorer emotional well-being and poorer social functioning among Veterans.73 A 2008 literature review74 cited numerous studies finding PTSD negatively impacted family functioning, but its references to Veteran-specific literature were limited in both number and strength of findings. In contrast, Magruder and colleagues47 did not find any association, in their random sample of male primary care patients at two VAMCs, between PTSD and social support (as measured by living alone or with someone). Rosenheck, Leda and Gallup,75 in their analysis of 1988-1989 data from homeless male Veterans seeking residential treatment or intensive case management for mental illness, did not find any significant association between Veterans with “combat stress” (a measure defined using PTSD diagnostic criteria) and social adjustment as measured by marriage, employment or justice system history. However, the authors pointed out that this was likely to be a result of their sampling limitations, and that compared to the general population of Veterans at the time, the entire sample exhibited “severe social and vocational problems,” suggesting the underlying impact of mental illness on multiple intermediate outcomes that might increase the risk of homelessness.

### Some Exposures, Like Alcohol/Drug Abuse and Low Social Support, That May Increase Risk of Homelessness Frequently Emerge During Service or the Readjustment Period

Drug and/or alcohol abuse, though widely studied and popularly accepted as risk factors for homelessness, have not been consistently shown to increase the risk of homelessness among Veterans. There is limited evidence suggesting that alcohol and drug use increase the risk of homelessness, but there are many potential confounding factors. While exposure to these risk factors is not intrinsic to military service, evidence suggests that military culture and/or the inherently disruptive nature of military service tours increase the likelihood of negative outcomes for both alcohol/drug abuse and social support. These weak associations with the onset of alcohol/drug abuse and low social support post-service explain why “military service” in general is included in the conceptual model, even though in other ways (through employment and educational training, for example) military service may provide protection against homelessness.

A higher prevalence of problem alcohol use has been shown among Veterans compared to the general populations. Kulka et al. found that 40 percent of male Veterans had abused alcohol for some period in their lives, compared to 25 percent among male civilians.44 While results varied by race and sex, the general finding of the NVVRS was that problem alcohol and substance use, though higher among both male and female Veterans than among the general population, was not higher among male Vietnam theater Veterans compared to male Vietnam era Veterans. 44 More recently, Erbes and colleagues, examining a small, self-selecting sample of OEF/OIF Veterans enrolling at a VAMC, found 27 percent reported current (as opposed to lifetime) hazardous drinking practices. 73

Bray and Hourani52 analyzed data from cross-sectional Department of Defense surveys of active duty service members conducted regularly between 1980 and 2005. Their analysis found that, despite earlier declines in heavy drinking in 2005, more than one in six active duty personnel were likely to be heavy drinkers.52 These findings lend support to concerns cited by the authors that military culture, in contrast to its attitudes towards smoking and illicit drug use, remains permissive of problem alcohol use; the influence of this experience while in the military may shape post-service behavior. Arguably, rates of alcohol and drug use among active duty service members might reflect usage in the general population in their age cohort, especially for younger cohorts among whom substance use is generally believed to be highest. However, Bray and Hourani’s analysis did control for socio-demographic trends on substance use and still found no decline. 52 More significantly, Jacobson and colleagues conducted a longitudinal study that collected baseline and post-deployment data on alcohol use, and found that the Reserve and National Guard personnel and younger service members who deployed with combat exposures were more likely to develop new problem alcohol use during the post-deployment period, and that this risk was greatest among those also diagnosed with PTSD or PTSD and depression.53 This finding suggests an alternate concern: that problem alcohol use may be related not just to the immediate stresses or “culture” of military service but also to its after-effects. Rosenheck, Leda and Gallup75 using data from homeless male Veterans seeking residential treatment in the late 1980s, had previously found an association (p<.02) between “combat stress” – defined by Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) PTSD symptoms – and alcohol problems, along with a marginally significant association between combat stress and substance use. Similarly, Benda’s (2006) study of Veterans seeking domiciliary care for substance abuse found a negative association between PTSD severity and the length of time before readmission. All of these findings highlight, again, the inter-connection of potential risk factors.

However, the evidence on the association between alcohol and/or drug use problems and homelessness is limited. Rosenheck and Fontana’s analysis of NVVRS data15 found that substance abuse, particularly alcohol abuse, had a direct effect on risk of homelessness. Tessler, Rosenheck and Gamache55 found that homeless Veterans scored significantly higher on the ASI-Alcohol score than homeless non-Veterans, suggesting that alcohol problems may be more common to the experiences of homeless Veterans. The study found no significant difference in mean ASI-Drugs scores in the two populations, but did find younger Veteran cohorts (those born after 1953) scored significantly higher on the ASI-Drugs score than did older cohorts. Age is only one factor that may be of relevance in understanding differences in risk related to substance use within the homeless Veteran population. The NVVRS, for example, found that drug and alcohol abuse problems were most pronounced among Hispanic combat Veterans,44 and another study that focused on homeless Native American Veterans76 found they were more likely than other homeless Veterans to have an alcohol use problem, but less likely to have drug use problems (or a psychiatric diagnosis). Leda, Rosenheck and Gallup77 found, among their sample of homeless mentally ill Veterans seeking treatment, that substance abuse diagnoses were less common among women than among men. Benda78 found that, among a random sample of homeless male Veterans seeking domiciliary care, combat exposure was on a par with alcohol and drug abuse as a predictor for readmission for substance abuse treatment (HR 1.56-1.97 CI, p<.01); the female sample did not have sufficient combat exposure to test this association, but as Benda suggests, this is likely to have changed as more women are exposed to combat-like conditions.78

### Military Sexual Trauma (MST) May Place Veterans at Increased Risk of Homelessness

Awareness of the problem of MST has increased dramatically in the past decade,79 although evidence indicates that sexual harassment and assault, especially, but not only, directed against female service members occurred in earlier eras of service as well. A 1999 study of female VA outpatients found military sexual assault was reported by 23 percent of respondents;80 another study from the 1990s of inpatient and randomly selected outpatient female Veterans at one VAMC similarly found that 14 percent of female Veterans under age 50 reported attempted rape during military service.81 Kimerling’s analysis of data from over 125,000 OEF/OIF Veterans, who are now routinely screened for MST, found a prevalence of 15.1 percent positive MST screening among women and 0.7 percent positive screening among men.82

The only study to date which has examined the association between MST and homelessness is Washington, Yano and McGuire’s study of housed and non-housed female Veterans in the Los Angeles area.36 That study found that sexual assault during military service was associated with Veteran homelessness. Kimerling did not look at housing outcomes, but found significant associations between positive MST screening and PTSD diagnosis, other anxiety disorders, depression, adjustment disorder, substance disorder or alcohol disorder.82 Benda’s study constructed hazard models which indicated that sexual and physical abuse, regardless of when they occurred (in childhood or adulthood, during or after military service), were stronger predictors of readmission to substance abuse treatment for homeless female Veterans than for homeless male Veterans, who rarely reported military sexual or physical abuse.78 Hankin and colleagues found that female Veterans who reported having ever experienced sexual assault were twice as likely to report current alcohol abuse and three times as likely to report symptoms of depression.80 A 2003 literature review83 studied mental service utilization among female Veterans and concluded that sexual trauma, whether service-related or not, was associated with PTSD. Murdoch and Nichol found that sexual harassment while in the military – which was experienced by 90 percent of female Veterans under age 50 in the sample – was significantly associated with an increased risk of anxiety, depression, and poorer general health on three different measures, all of which could contribute cumulatively to increased risk for homelessness.81

Sexual and physical abuse are probably under-reported both inside and outside of military settings, and given the fact that non-military related sexual abuse cannot be service-connected, there is an especial risk that it remains under-reported among Veterans.83 It has been argued that female Veterans suffer from higher rates of PTSD than male soldiers and have experienced higher rates of sexual assault than the general population. 16 Experience with sexual assault has been linked to PTSD, depression, alcohol and drug abuse, disrupted social networks, and employment difficulties, all factors known to increase one’s risk for homelessness. 16 The possibility that there is a cumulative effect of abuse on an individual’s resiliency or well-being, coupled with poor confidence in rates of reporting, make it difficult to determine to what extent MST acts as an independent risk factor for homelessness. Given the range of associated outcomes, it may be that MST, like combat exposure, exerts greater influence on intermediate outcomes than on homelessness itself. Further research into the extent of MST’s association with these outcomes is recommended.

## KEY QUESTION #4 What is the relationship between incarceration and homelessness among Veterans?

After a steady rise in the number of Veterans in prison since 1985, the number, which peaked at about 153,100 in 2000, had declined by about nine percent to 140,000 by 2004.^84^ The age adjusted incarceration rate for Veterans, which accounts for the older distribution of the Veteran population when compared to the general population, is about 1,253 per 100,000 or about 10 percent lower than the rate for non-Veterans. An older study of mentally ill Veterans found 15.7 percent had an incarceration history.85 A more recent national study found three percent of Veterans were incarcerated. 86

Incarcerated Veterans were more likely to have committed violent offenses than the incarcerated non-Veteran population. 84 Over half of Veterans serving in state prisons (57 percent), but fewer than half of non-Veterans (47 percent) were in prison for violent offenses. While about 20 percent of non-Veterans were incarcerated for homicide (12 percent) or rape/sexual assault (9 percent), over a third of Veterans were serving sentences for homicide (15 percent) and rape/ sexual assault (23 percent). A similar pattern is found for active-duty personnel held in military prison. In 2004, 46 percent of all inmates in military custody were incarcerated for violent offenses, with rape or sexual assault being the most common reason for incarceration, accounting for 29 percent of inmates in military prisons.84

Incarcerated Veterans have also been found to have higher rates of drug abuse,85, 87-89 treatment for mental health disorders,85-87 and PTSD87 than unincarcerated Veterans. On the other hand, incarcerated Veterans have comparable rates of alcohol abuse and mental health disorders, and lower rates of drug use than incarcerated non-Veterans.84

Finally, while Veterans in federal prison were twice as likely to be White, non-Hispanic (49 percent) as non-Veterans (24 percent), incarceration patterns for Veterans showed the same types of racial and ethnic disparities in imprisonment as in the general population. While the 2005-2007 American Community Survey estimated that 82 percent of Veterans were White, non-Hispanic, 10 percent Black, and 5 percent Hispanic in 2004; 49 percent of Veterans in federal prisons were White, non-Hispanic, 38 percent were Black, and 5 percent were Hispanic. In state prisons 54 percent of Veterans were White, 32 percent Black, and 6 percent Hispanic.84

### Incarceration and Homelessness

In a review of the literature on incarceration and homelessness, Metraux and colleagues note the demographic similarities between homeless and incarcerated populations – both are typically poor, uneducated, and minority populations with few job skills – and suggest a bi-directional association between homelessness and incarceration.90 They found that about 10 percent of those entering prison have a recent history of homelessness, and that at least 10 percent of those leaving prison experience some period of subsequent homelessness. In reviewing studies of the homeless, they found that as many as 20 percent of the adult homeless population is likely to have some lifetime experience of incarceration.

Metraux et al. found in their review of the literature that inmates of local jails, as opposed to state or federal prison inmates, had a cyclic pattern of homelessness and incarceration leading to prolonged residential instability. In contrast, because prisons are often located remotely from inmates’ local communities, social ties that may be necessary to support successful integration upon release are often disrupted. Inmates of prison, therefore, are more likely to become homeless within 30 days of release.90

In exploring the factors associated with homelessness among the incarcerated, their review found shelter use prior to incarceration to be the strongest predictor of shelter use upon re-entry from prison. Other factors found to be associated with homelessness among the incarcerated include:

- Ineffective discharge planning: Prisons are generally remote from the communities to which prisoners will be returning, making access with local service agencies difficult;
- Legal and regulatory restrictions: Many laws limit access to public housing, drivers’ licenses, and eligibility for government financial support programs;
- Full sentencing laws: Laws requiring sentence completion mean fewer prisoners are released on parole and probation, eliminating a source of support and supervision during the period of re-integration into the community; and
- Financial instability: Loss of job skills and reluctance of employers to hire former convicts can make it difficult to earn enough to make rent payments.90

In addition to factors that put prisoners at risk for subsequent homelessness, the review points to the “criminalization” of many of the activities of the homeless as factors increasing their risk for incarceration. This leads to what the review describes as an “‘institutional circuit,’ where a series of institutions provide sequential stints of housing in place of a stable, community-based living situation.”90

#### Legal and Regulatory Barriers

A recently updated report by the Legal Action Center, After Prison: Roadblocks to Reentry,91 describes the barriers faced by people with criminal records. Particularly for those with drug-related offenses, these barriers include restrictions on driving, limits on access to public assistance programs, and limits on access to public housing. Several studies have pointed to the impact of child support requirements on incarcerated parents, noting that incarcerated parents with child support obligations on average owe $10,000 upon entering prison, and owe on average $20,000 when released.92, 93 Minimum wage workers have little hope of making the typical monthly payment obligations of from $225 to $300 per month, often leading to further financial and legal difficulties. This problem is of particular relevance noting that in the most recent CHALENG report, legal assistance for child support was ranked as the second highest unmet need of responding homeless Veterans. 26

### Studies of Homelessness and Incarceration among Veterans

Very few studies have specifically investigated homelessness and incarceration in the Veteran population. The most salient feature of the literature is its sparseness. However, those few studies support the broader evidence that suggests that homelessness and incarceration have a bi-directional relationship.90 Homelessness, through the criminalization of the activities of daily living while homeless, such as panhandling, vagrancy, trespassing, and public urination; and through criminal activities taken on either to cope with homelessness, such as alcohol and drug use, or to survive, such as stealing and prostitution, often leads to incarceration. Conversely, incarceration, by its separation from home communities and through legal restrictions on re-integration with those communities, often puts individuals at risk for homelessness upon release.

A 2003 study assessed whether substance abuse and psychiatric illness are related to offenses, and attempted to identify the strongest predictors of and protective factors against criminal offenses among homeless Veterans with substance abuse problems (n = 188).94 Measures included the Addiction Severity Index (ASI); the Multi-Problem Screening Inventory (MPSI); the Multidimensional Scale of Perceived Social Support; the Self-Efficacy Scale; and the Ego Identity Scale. Respondents were found to be representative of the population from which they were drawn. Half were White, about 40 percent were Black, and most had lived in a rural area during adolescence; and there were high levels of depression and suicidality. One-third (33 percent) reported no offenses in the past year and 41 percent reported committing multiple offenses. Alcohol abuse (OR = 2.04, 95% CI = 1.80, 2.30), drug abuse (OR = 3.57, 95% CI = 3.01, 4.05), and number of prior psychiatric hospitalizations (OR = 1.27, 95% CI = 1.15, 1.39) were significantly associated with committing a crime in the past year, while depression and suicidal thoughts were not. In a separate analysis, those sexually abused before age 18 were two and a half times more likely to have committed a crime in the past year (OR = 2.50, 95% CI = 2.33, 2.70). On the other hand, those with a strong sense of self-efficacy, resilience, or ego-integrity were significantly less likely to have committed a crime in the past year (OR = 0.28, 95% CI = 0.17, 0.41; OR = 0.32, 95% CI = 0.20, 0.47; OR = 0.48, 95% CI = 0.40, 0.58, respectively). Those who reported usual, full-time employment in the previous three years were about half as likely to have committed a crime in the previous year (OR = 0.46, 95% CI = 0.30, 0.61) and higher levels of education were associated with lower likelihood of committing a crime (OR = 0.57, 95% CI = 0.43, 0.71). The authors suggest that in homeless Veterans who abuse substances, co-morbid mental health problems may increase the likelihood of incarceration; but that even among this population, a strong sense of self-efficacy, resilience, and ego-integrity can reduce the likelihood of incarceration.94

A study of patients with serious mental health disorders recruited from a VA mental institution found that lifetime homelessness was most strongly associated with lifetime history of incarceration (OR = 4.36, 95% CI = 2.73, 6.94) but was also associated with lower levels of treatment adherence (OR = 0.80, 95% CI = 0.66, 0.96 ); that recent homelessness (in the previous four weeks) was strongly associated with recent incarceration (OR = 26.41, 95% CI = 5.23, 133.4); and those who had any lifetime experience of homelessness were four times more likely to have a lifetime history of incarceration (OR = 4.24, 95% CI = 2.67, 6.71). While the authors note that these findings suggest a strong bi-directional association of homelessness and incarceration, the findings may not be generalizable beyond VA patients with bipolar disorders.95

A small study (n= 62) evaluated self-selected, mentally ill Veteran inmates who were either homeless at the time of arrest or anticipated being homeless after release.96 Most were Black (74 percent) and unmarried (89 percent). Over a quarter (26 percent) were homeless at the time of arrest, and three-quarters (75 percent) had had a prior episode of homelessness. Nearly all subjects (94 percent) reported a prior arrest and 73 percent were being detained on felony charges. The primary psychiatric diagnoses were schizophrenia (37 percent), mood disorders (35 percent), PTSD (5 percent), adjustment disorders (5 percent), and pedophilia (3 percent). Eighty-three percent reported either a diagnosis of substance abuse disorder or significant problems with alcohol and drugs, and 76 percent reported a history of prior psychiatric hospitalization. The authors suggest the study shows that large urban jails may be useful locations for outreach to mentally ill, homeless Veterans.96

#### Jail Diversion Programs for Veterans

Because of the strong association between homelessness and incarceration, interventions that divert offenders from prison have been seen by some as promising approaches both to limit the direct negative effects of incarceration and to mitigate the association of incarceration with subsequent homelessness. The literature on diversion programs specifically targeting Veterans is very sparse, as such programs are relatively new. However, more general diversion programs have a long history dating back to the 1970s, and there is a large body of literature both describing and evaluating the effectiveness of these programs. A comprehensive and systematic review of that literature is beyond the scope of this review. However, because of the potential importance of these programs in addressing issues of homelessness, we provide a brief overview of the various types of diversion programs that have been developed.

Broadly, diversion programs fall into two categories, pre-booking vs. post-booking diversion. In pre-booking programs, individuals are diverted prior to arrest, often through the discretion and decision of specially trained police. In post-booking programs, individuals are diverted after arrest but before prosecution and incarceration, and the program is generally overseen by the court. This review will focus on post-booking programs, as they are generally the more formal programs and the better-studied.

Post-booking programs operate either out of standard criminal courts or out of specialty courts that target specific types of offenders such as the mentally ill, drug users and, more recently, Veterans. Early diversion programs focused on diverting mentally ill offenders from jail and towards treatment options with a goal to reducing jail time and recidivism, and providing effective mental health treatment. In an early survey of jail diversion programs for the mentally ill, Steadman and colleagues provided a definition of jail diversion programs as “specific (formal or informal) programs that screen defined groups of detainees for the presence of mental disorder; use mental health professionals to evaluate all those detainees identified in the screening; and negotiate with prosecutors, defense attorneys, community-based mental health providers, and the courts to produce a mental health disposition outside the jail in lieu of prosecution or as a condition of a reduction in charges (whether or not a formal conviction occurs)” (italics in the original). 97

In 1995, the SAMHSA established the National GAINS Center as a locus for the collection and dissemination of information on effective mental health and substance abuse programs for individuals with co-occurring disorders who come into contact with the justice system (web site at: http://gainscenter.samhsa.gov/html). Between 2002 and 2007, through its Center for Mental Health Services (CMHS), SAMHSA provided Targeted Capacity Expansion (TCE) grants to support the development of evidence-based jail diversion programs. This funding only supported programs that operated out of traditional court programs; funding could not support programs operating out of specialty courts. With recognition of the increasing number of combat Veterans returning from overseas with PTSD and of the associated risk for involvement with the criminal justice system, in 2008, CMHS began funding a Jail Diversion and Trauma Recovery Program to support implementation and expansion of jail diversion programs specifically for individuals with PTSD and other trauma-related disorders, providing prioritized eligibility for Veterans. Since 2008, CMHS has awarded 13 grants through this program. All programs have specific and similar requirements for program evaluation and standard data elements for collection.

A national multi-site evaluation of the programs funded through the TCE grants found mixed results among the programs and overall. The most consistent effect was an increase in service utilization, with diversion being associated with increases in counseling, mental health hospitalizations, emergency room use, and use of mental health medications. However, this effect was found, in general, to decrease in time with service utilization, being lower at the 12-month follow-up period than at three months. In addition, while differences in access to and quantity of treatment were significant, treatment intensity in both groups, diverted and non-diverted, were low.98 Findings were mixed for changes in drug and alcohol use, with some sites showing decreased use while others showed increased use for both drug and alcohol use, and there was little evidence of effectiveness on mental health outcomes or quality of life. Across all sites, diversion programs resulted in significant increases in days at risk (not institutionalized) and days in the community, and fewer days in jail. However, there was no change in recidivism.

The findings from this study are consistent with the findings of other studies and reviews.99-103 Some care should be taken in interpreting these findings as studies varied in quality and there was substantial variation in the characteristics of the programs evaluated. Nevertheless, the lack of significant findings on a number of outcomes and the consistency of findings related to criminal justice outcomes suggests that what biases there were likely did not act to overestimate the effectiveness of these programs. If true, these findings suggest that while diversion programs may not be effective in treating the mental health needs of the participants, that from a public policy and safety perspective, diversion programs can lead to reduced days in jail and increased days in the community without increasing risks for public safety.

Finally, with regard to issues related to homelessness, one evaluation of these same programs found that consistent housing throughout the 12-month study period was the factor most strongly associated with post-enrollment arrests. The only other factors significantly associated with no vs. any post-enrollment arrest was prior arrests and number of prior jail days.99 These findings underscore the importance of stable housing for successful diversion programs.

#### Mental Health and Drug Courts

While many of the earlier programs and their evaluations were limited to diversion programs overseen by the traditional court system, later programs, in an attempt to enhance program effectiveness, developed a model of specialty mental health and drug courts which sought to bring together the experts and resources needed for effective oversight and treatment of these detainees. In his review of studies of diversion programs for persons with mental illness, Sirotich101 looked at six studies in which diversion programs were overseen by mental health courts. Similar to the findings for non-specialty courts, Sirotich found inconsistent results among the programs supervised by mental health courts, with the most consistent finding being that divertees showed no increase in the number of jail days relative to those not diverted; two studies reported a decrease in jail time for mental health court participants but not for those receiving treatment as usual; and two studies reported no change in jail time for either group.101 Finally, in a review of drug court effects on recidivism, Wilson and colleagues found offenders participating in drug courts less likely to re-offend than those treated with traditional justice programs.104 That review found weak evidence that effectiveness varied by the specific drug court model employed. Programs that dismissed charges or expunged records appeared to be more successful than those in which the incentives for successful completion were more ambiguous. Programs that used a single treatment provider appeared slightly more successful than those providing treatment by multiple providers. Regardless of model, studies were inconclusive as to whether effectiveness would persist after the individual left the program.

#### Veterans Courts

Noting an increase in the number of Veterans appearing in court for criminal offenses often related to substance abuse and mental health disorders, and building on the models of mental health and drug courts, a number of jurisdictions have begun to develop Veterans Courts. The first such court was established in Anchorage, Alaska in 2004^105^ to provide an alternative to jail time for Veterans charged with misdemeanors. In 2009, Judge Robert T. Russell described the 10 Key Components of the Veterans Treatment Court of Buffalo, New York, which was established in January 2008. These components were modeled on the key components of drug courts as described by the U.S. Department of Justice.106 As noted above, it was about that time that SAMHSA began funding to support Jail Diversion and Trauma Recovery Programs with priority for program eligibility given to Veterans. That program now provides support and technical assistance to programs in 13 states, including Colorado, Connecticut, Georgia, Illinois, Massachusetts, and Vermont (funded in 2008); Florida, North Carolina, New Mexico, Ohio, Rhode Island and Texas (funded in 2009); and Pennsylvania (funded in 2010). Veterans Courts have also been established in Tulsa, Oklahoma and Nevada; and California law allows the court to grant special consideration to anyone who alleges that he or she has committed an offense as a result of sexual trauma, traumatic brain injury, PTSD, substance abuse, or a mental health problem as a result of military service. 107 In addition, a Department of Veterans Affairs Information Letter reported that as of April 2009 more than one third of VAMCs indicated that they currently engaged or intended to engage with local justice system partners to coordinate services for justice-involved Veterans. 108 Likely because these programs are new, we have found no studies evaluating their effectiveness.

Veterans leaving prison are at high risk for homelessness because of the many social and legal barriers to re-integration. That makes prisons a good place to do outreach to Veterans at risk for homelessness. However, to address the problem will require a multi-modal approach that brings together the corrections agencies responsible for releasing the Veteran, the justice system responsible for parole or probationary oversight, the mental health system in the community where the Veteran will be released to help address any psychiatric and substance use problems, the local VA and Veterans Health Administration (VHA) agencies, and the local housing agencies to help link the Veteran to housing or supportive housing as needed. This will require not only developing new collaborative approaches, but also sponsoring research on ways in which these collaborations (and which types of collaborations) can most effectively reduce the likelihood of homelessness upon re-entry, including developing a better understanding of how to identify those most at risk for homelessness post-release.

Conversely, homeless Veterans are at risk for imprisonment because of the criminalization of the activities of daily living while homeless, and as a result of activities to help cope and survive while homeless. To break the cycle of homelessness⇒incarceration⇒homelessness, the VA should encourage research on Veterans Courts to determine how to implement them so as to effectively divert already homeless Veterans (or Veterans at risk for homelessness because of criminal activities) from increasing their risk for continued (or new) homelessness by creating opportunities to avoid prison and the negative consequences deriving from both a criminal record and incarceration.