# REFERENCES

1 Homeless on Veterans Day. The New York Times. November. 11. 2009.
2 US Interagency Council on Homelessness. Opening Doors, Federal Strategic Plan to Prevent and End Homelessness. 2010.
3 Elliott M, Krivo LJ. Structural Determinants of Homelessness in the United States. Social Problems. 1991;38(1):113-31.
4 Ji E-G. A study of the structural risk factors of homelessness in 52 metropolitan areas in the United States. Int Socl Work. 2006;49(1):107-17.
5 Lee BA, PriceSpratlen T, Kanan JW. Determinants of Homelessness in Metropolitan Areas. Journal of Urban Affairs. [doi: 10.1111/1467-9906.00168]. 2003;25(3):335-56.
6 O’Connell MJ, Kasprow W, Rosenheck RA. Rates and risk factors for homelessness after successful housing in a sample of formerly homeless veterans. Psychiatr Serv. Mar. 2008;59(3):268-75. [pmid: 18308907].
7 Shinn M, Weitzman BC, Stojanovic D, Knickman JR, Jimenez L, Duchon L, et al. Predictors of homelessness among families in New York City: from shelter request to housing stability. American Journal of Public Health. [Research Support, Non-U.S. Gov’t Research Support, U.S. Gov’t, P.H.S.]. Nov. 1998;88(11):1651-7. [pmid: 9807531].
8 Koegel P, Burnam MA, Baumohl J. The causes of homelessness. Baumohl J, editor. Homelessness in America. Phoenix. The Oryx Press. 1996:24-33.
9 DeCrappeo M, Pelletiere D, Crowley S, Teater E. Renters in the great recession, the crisis continues. National Low Income Housing Coalition. 2010. June.
10 Daskal J. In search of shelter: The growing shortage of affordable rental housing. Washington, DC. Center on Budget and Policy Priorities. 1998.
11 National Coalition for the Homeless. Why Are People Homeless?. 2009. July.
12 Pelletierre D. The rental housing affordability gap: Comparison of 2001 and 2003 American Housing Surveys. National Low Income Housing Coalition. 2006. March.
13 Dolbeare C. Housing policy: A general consideration. Baumohl J, editor. Homelessnes in America. Phoenix. The Oryx Press. 1996:34-45.
14 The 2009 Annual Homeless Assessment Report to Congress. Office of Community Planning and Development, U.S. Department of Housing and Urban Development. June. 2010.
15 Rosenheck R, Fontana A. A model of homelessness among male veterans of the Vietnam War generation. Am J Psychiatry. Mar. 1994;151(3):421-7. [pmid: 8109652].
16 Perl L. Veterans and Homelessness. Congressional Research Service. 2009;(2009 June 26).
17 Dietz TL. Predictors of reported current and lifetime substance abuse problems among a national sample of U.S. homeless. Subst Use Misuse. 2007;42(11):1745-66. [pmid: 17934993].
18 Johnson TP, Fendrich M, Johnson TP, Fendrich M. Homelessness and drug use: evidence from a community sample. Am J Prev Med. [Research Support, N.I.H., Extramural]. Jun. 2007;32(6 Suppl):S211-8. [pmid: 17543713].
19 Susser E, Moore R, Link B. Risk factors for homelessness. Epidemiol Rev. [Review]. 1993;15(2):546-56.
20 Fischer P, Breakey W. The epidemiology of alcohol, drug, and mental disorders among homeless persons. Am Psychol. 1991;46(11):1115-28. [pmid: 1772149].
21 Shelton KH, Taylor PJ, Bonner A, van den Bree M, Shelton KH, Taylor PJ, et al. Risk factors for homelessness: evidence from a population-based study. Psychiatric Services. [Research Support, N.I.H., Extramural]. Apr. 2009;60(4):465-72. [pmid: 19339321].
22 Johnson TP, Freels SA, Parsons JA, Vangeest JB. Substance abuse and homelessness: social selection or social adaptation?. Addiction. [Research Support, Non-U.S. Gov’t]. Apr. 1997;92(4):437-45. [pmid: 9177065].
23 Phelan JC, Link BG. Who are “the homeless”? Reconsidering the stability and composition of the homeless population. American Journal of Public Health. [Research Support, U.S. Gov’t, P.H.S. Review]. Sep. 1999;89(9):1334-8. [pmid: 10474549].
24 Snow DA, Anderson L, Koegel P. Distorting Tendencies in Research on the Homeless. American Behavioral Scientist. 1994;37(4):15.
25 Cackley AP, Schmidt P, Barry NS, Boggs K, Burnett R, Chatlos W, et al. Homelessness: A common vocabulary could help agencies collaborate and collect more consistent data. United States Government Accountability Office. 2010.
26 Kuhn JH, Nakashima J. The Sixteenth Annual Progress Report: Community Homelessness Assessment, Local Education and Networking Group for Veterans - Services for homeless veterans assessment and coordination. Community Homelessness Assessment, Local Education and Networking Group for Veterans. March. 17. 2010.
27 Veteran Homelessness: A Supplemental Report to the 2009 Annual Homeless Assessment Report to Congress. Office of Community Planning and Development, U.S. Department of Housing and Urban Development and the U.S. Department of Veteran Affairs. January. 2011.
28 Farrell BS, Gosling TW, Keisling SE, Nalwalk KM, Petrucci S, Shoemaker LL. Military personnel: Active duty benefits reflect changing demographics, but opportunities exist to improve United States Government Accountability Office. 2002.
29 Stewart DB. Military personnel: Active duty benefits reflect changing demographics, but continued focus is needed United States Government Accountability Office. 2002.
30 Health ViEWS: Health of Vietnam Era Women’s Study. 2011. [cited 2011 March 9, 2011]; Available from: http://www.research.va.gov/programs/csp/csp579.cfm.
31 The Millenium Cohort Study. 2011. [cited 2011 March 9, 2011]; Available from: http://www.millenniumcohort.org/index.php.
32 Link B, Phelan J, Bresnahan M, Stueve A, Moore R, Susser E. Lifetime and five-year prevalence of homelessness in the United States: new evidence on an old debate. American Journal of Orthopsychiatry. [Research Support, U.S. Gov’t, P.H.S.]. Jul. 1995;65(3):347-54. [pmid: 7485420].
33 Cunningham M, Henry M, Lyons W. Vital mission - Ending homelessness among veterans. National Alliance to End Homelessness. 2007. November.
34 Institute of Medicine Committee on the Initial Assessment of Readjustment Needs of Military Personnel V, Their F. Returning home from Iraq and Afghanistan: Preliminary assessment of readjustment needs of veterans, service members and their families. 2010.
35 Winkleby MA, Fleshin D. Physical, addictive, and psychiatric disorders among homeless veterans and nonveterans. Public Health Rep. Jan-Feb. 1993;108(1):30-6. [pmid: 8434094].
36 Washington D, Yano EM, McGuire J. Risk factors for homelessness among women veterans. Journal of Health Care for the Poor and Underserved. February 2010. 2010;21:82-91. [pmid: 20173257].
37 O’Toole TP, Conde-Martel A, Gibbon JL, Hanusa BH, Fine MJ. Health care of homeless veterans. J Gen Intern Med. Nov. 2003;18(11):929-33. [pmid: 14687279].
38 Wenzel SL, Gelberg L, Bakhtiar L, Caskey N, Hardie E, Redford C, et al. Indicators of chronic homelessness among veterans. Hosp Community Psychiatry. Dec. 1993;44(12):1172-6. [pmid: 8132190].
39 Adams J, Rosenheck R, Gee L, Seibyl CL, Kushel M. Hospitalized younger: a comparison of a national sample of homeless and housed inpatient veterans. J Health Care Poor Underserved. Feb. 2007;18(1):173-84. [pmid: 17337806].
40 Koegel P, Melamid E, Burnam MA. Childhood risk factors for homelessness among homeless adults. Am J Public Health. [Research Support, U.S. Gov’t, P.H.S.]. Dec. 1995;85(12):1642-9. [pmid: 7503338].
41 Susser ES, Lin SP, Conover SA, Struening EL. Childhood antecedents of homelessness in psychiatric patients. American Journal of Psychiatry. [Research Support, Non-U.S. Gov’t]. Aug. 1991;148(8):1026-30. [pmid: 1853951].
42 Rosenheck R, Koegel P. Characteristics of veterans and nonveterans in three samples of homeless men. Hosp Community Psychiatry. Sep. 1993;44(9):858-63. [pmid: 8225299].
43 Department of Defense Task Force on Mental Health. An achievable vision: Report of the Department of Defense Task Force on Mental Health. Falls Church, VA. Defense Health Board. 2007.
44 Kulka R, Schlenger W, Fairbank J, Hough R, Jordan B. Trauma and the Vietnam War generation: report of the findings from the National Vietnam Veterans Readjustment Study. New York. Brunner/Mazel. 1990.
45 Goldberg J, True W, Eisen S, Henderson W. A twin study of the effects of the Vietnam War on Posttraumatic Stress Disorder. Journal of the American Medical Association. 1990;263(9):1227-32. [pmid: 2304238].
46 Roy-Byrne P, Arguelles L, Vitek ME, Goldberg J, Keane TM, True WR, et al. Persistence and change of PTSD symptomatology--a longitudinal co-twin control analysis of the Vietnam Era Twin Registry. Social Psychiatry & Psychiatric Epidemiology. [Research Support, U.S. Gov’t, Non-P.H.S. Research Support, U.S. Gov’t, P.H.S. Twin Study]. Sep. 2004;39(9):681-5. [pmid: 15672287].
47 Magruder KM, Frueh BC, Knapp RG, Johnson MR, Vaughan JA 3rd, Carson TC, et al. PTSD symptoms, demographic characteristics, and functional status among veterans treated in VA primary care clinics. Journal of Traumatic Stress. [Research Support, U.S. Gov’t, Non-P.H.S.]. Aug. 2004;17(4):293-301. [pmid: 15462536].
48 Hoge CW, Auchterlonie JL, Milliken CS, Hoge CW, Auchterlonie JL, Milliken CS. Mental health problems, use of mental health services, and attrition from military service after returning from deployment to Iraq or Afghanistan. Jama. [Research Support, U.S. Gov’t, Non-P.H.S.]. Mar 1. 2006;295(9):1023-32. [pmid: 16507803].
49 Seal KH, Metzler TJ, Gima KS, Bertenthal D, Maguen S, Marmar CR, et al. Trends and risk factors for mental health diagnoses among Iraq and Afghanistan veterans using Department of Veterans Affairs health care, 2002-2008. American Journal of Public Health. [Research Support, Non-U.S. Gov’t Research Support, U.S. Gov’t, Non-P.H.S.]. Sep. 2009;99(9):1651-8. [pmid: 19608954].
50 Polusny MA, Erbes CR, Arbisi PA, Thuras P, Kehle SM, Rath M, et al. Impact of prior Operation Enduring Freedom/Operation Iraqi Freedom combat duty on mental health in a predeployment cohort of National Guard soldiers. Military Medicine. [Research Support, Non-U.S. Gov’t Research Support, U.S. Gov’t, Non-P.H.S.]. Apr. 2009;174(4):353-7. [pmid: 19485103].
51 Maclean A. The things they carry: combat, disability and employment among U.S. men. Am Sociol Rev. 2010;75(4):563-85. [pmid: 21818157].
52 Bray R, Hourani L. Substance use trends among active duty military personnel: findings from the United States Department of Defense Health Related Behavior Surveys, 1980-2005. US Department of Defense. 2007. Report No.: Addiction 102.
53 Jacobson IG, Ryan MA, Hooper TI, Smith TC, Amoroso PJ, Boyko EJ, et al. Alcohol use and alcohol-related problems before and after military combat deployment. Jama. [Research Support, N.I.H., Extramural Research Support, U.S. Gov’t, Non-P.H.S.]. Aug 13. 2008;300(6):663-75. [pmid: 18698065].
54 Rosenheck R, Kasprow W, Frisman L, Liu-Mares W. Cost-effectiveness of supported housing for homeless persons with mental illness. Arch Gen Psychiatry. Sep. 2003;60(9):940-51. [pmid: 12963676].
55 Tessler R, Rosenheck R, Gamache G. Comparison of homeless veterans with other homeless men in a large clinical outreach program. Psychiatr Q. Summer. 2002;73(2):109-19. [pmid: 12025719].
56 Sherbourne CD, Stewart AL. The MOS social support survey. Soc Sci Med. 1991;32(6):705-14. [pmid: 2035047].
57 Lin N, Dean A, Ensel WM. Social support, life events, and depression. Academic Pr. 1986.
58 Rosenheck R, Frisman L, Chung AM. The proportion of veterans among homeless men. Am J Public Health. Mar. 1994;84(3):466-9. [pmid: 8129068].
59 Vogt DS, Proctor SP, King DW, King LA, Vasterling JJ. Validation of scales from the Deployment Risk and Resilience Inventory in a sample of Operation Iraqi Freedom veterans. Assessment. Dec. 2008;15(4):391-403. [pmid: 18436857].
60 Saxon AJ, Davis TM, Sloan KL, McKnight KM, McFall ME, Kivlahan DR. Trauma, Symptoms of Posttraumatic Stress Disorder, and Associated Problems Among Incarcerated Veterans. Psychiatr Serv. [doi: 10.1176/appi.ps.52.7.959]. 2001;52(7):959-64. [pmid: 11433115].
61 Miller KE, Rasmussen A. War exposure, daily stressors, and mental health in conflict and post-conflict settings: Bridging the divide between trauma-focused and psychosocial frameworks. Social Science & Medicine. [doi: 10.1016/j.socscimed.2009.09.029]. 2010;70(1):7-16. [pmid: 19854552].
62 Koegel P, Burnam MA. Alcoholism among homeless adults in the inner city of Los Angeles. Archives of General Psychiatry. [Comparative Study Research Support, Non-U.S. Gov’t Research Support, U.S. Gov’t, P.H.S.]. Nov. 1988;45(11):1011-8. [pmid: 2460063].
63 Folsom D, Jeste DV. Schizophrenia in homeless persons: a systematic review of the literature. Acta Psychiatr Scand. Jun. 2002;105(6):404-13. [pmid: 12059843].
64 Reardon ML, Burns AB, Preist R, Sachs-Ericsson N, Lang AR. Alcohol use and other psychiatric disorders in the formerly homeless and never homeless: Prevalence, age of onset, comorbidity, temporal sequencing, and service utilization. Substance Use & Misuse. 2003;38(3-6):601-44. [pmid: 12747399].
65 Sullivan G, burnam A, Koegel P. Pathways to homelessness among the mentally ill. Soc Psychiatry Psychiatr Epidemiol. 2000;35:444-50. [pmid: 11127718].
66 Resnick SG, Rosenheck RA. Posttraumatic stress disorder and employment in veterans participating in Veterans Health Administration Compensated Work Therapy. J Rehabil Res Dev. 2008;45(3):427-35. [pmid: 18629751].
67 Smith MW, Schnurr PP, Rosenheck RA, Smith MW, Schnurr PP, Rosenheck RA. Employment outcomes and PTSD symptom severity. Mental Health Services Research. [Comparative Study Research Support, U.S. Gov’t, Non-P.H.S.]. Jun. 2005;7(2):89-101. [pmid: 15974155].
68 Savoca E, Rosenheck R. The civilian labor market experiences of Vietnam-era veterans: The influence of psychiatric disorders. J Men Health Policy Econ. 2000;3(4):199-207.
69 Harpham T, Grant E, Thomas E. Measuring social capital within health surveys: key issues. Health Policy Plan. Mar. 2002;17(1):106-11. [pmid: 11861592].
70 Irwin J, LaGory M, Ritchey F, Fitzpatrick K. Social assets and mental distress among the homeless: Exploring the roles of social support and other forms of social capital on depression. Social Science & Medicine. [doi: 10.1016/j.socscimed.2008.09.008]. 2008;67(12):1935-43. [pmid: 18930571].
71 An Achievable Vision: Report of the Department of Defense Task Force on Mental Health. U.S Department of Defense. 2007.
72 Committee on the Initial Assessment of Readjustment Needs of Military Personnel V, Their F, Board on the Health of Selected P, Institute of M. Returning Home from Iraq and Afghanistan: Preliminary Assessment of Readjustment Needs of Veterans, Service Members, and Their Families. Washington, D.C. The National Academies Press. 2010.
73 Erbes C, Westermeyer J, Engdahl B, Johnsen E, Erbes C, Westermeyer J, et al. Post-traumatic stress disorder and service utilization in a sample of service members from Iraq and Afghanistan. Military Medicine. Apr. 2007;172(4):359-63. [pmid: 17484303].
74 Karney B, Ramchand R, Osilla K, Caldarone L, Burns R. Predicting the immediate and long-term consequences of Post-Traumatic Stress Disorder, depression and traumatic brain injury in veterans of Operation Enduring Freedom and Operation Iraqi Freedom. Tanielian T, Jaycox L, editors. Invisible wounds of war: psychological and cognitive injuries, their cosequences, and services to assist recovery. Santa Monica, CA. Rand Corporation. 2008:119-66.
75 Rosenheck R, Leda C, Gallup P. Combat stress, psychosocial adjustment, and service use among homeless Vietnam veterans. Hosp Community Psychiatry. Feb. 1992;43(2):145-9. [pmid: 1572610].
76 Kasprow WJ, Rosenheck R. Substance use and psychiatric problems of homeless Native American veterans. Psychiatr Serv. Mar. 1998;49(3):345-50. [pmid: 9525794].
77 Leda C, Rosenheck R, Gallup P. Mental illness among homeless female veterans. Hosp Community Psychiatry. Oct. 1992;43(10):1026-8. [pmid: 1398567].
78 Benda BB. Survival analyses of social support and trauma among homeless male and female veterans who abuse substances. Am J Orthopsychiatry. Jan. 2006;76(1):70-9. [pmid: 16569129].
79 Report of the Defense Task Force of Sexual Assault in the Military Services | National Sexual Violence Resource Center (NSVRC). U.S. Department of Defense. 2009.
80 Hankin CS, Skinner KM, Sullivan LM, Miller DR, Frayne S, Tripp TJ. Prevalence of depressive and alcohol abuse symptoms among women VA outpatients who report experiencing sexual assault while in the military. Journal of Traumatic Stress. [Research Support, U.S. Gov’t, Non-P.H.S.]. Oct. 1999;12(4):601-12. [pmid: 10646179].
81 Murdoch M, Nichol KL. Women veterans’ experiences with domestic violence and with sexual harassment while in the military. Arch Fam Med. May. 1995;4(5):411-8. [pmid: 7742963].
82 Kimerling R, Street AE, Pavao J, Smith MW, Cronkite RC, Holmes TH, et al. Military-related sexual trauma among Veterans Health Administration patients returning from Afghanistan and Iraq. American Journal of Public Health. [Research Support, U.S. Gov’t, Non-P.H.S.]. Aug. 2010;100(8):1409-12. [pmid: 20558808].
83 Suffoletta-Maierle S, Grubaugh A, Magrude K, Monnier J, Frueh B. Trauma-related mental health needs and service utilization among female veterans. J Psychiatr Pract. 2003;9(5):367-75. [pmid: 15985955].
84 Noonan ME, Mumola CJ. Veterans in State and Federal Prison, 2004. US Department of Justice, Office of Justice Programs, Bureau of Justice Statistics. Washington, DC. 2007.
85 Rosenheck RA, Banks S, Pandiani J, Hoff R. Bed closures and incarceration rates among users of Veterans Affairs mental health services. Psychiatric Services (Washington, DC). 2000;51(10):1282-7.
86 Greenberg G, Rosenheck R. Mental Health and Other Risk Factors for Jail Incarceration Among Male Veterans. Psychiatric Quarterly. [doi: 10.1007/s11126-009-9092-8]. 2009;80(1):41-53. [pmid: 19184431].
87 Black DW, Carney CP, Peloso PM, Woolson RF, Letuchy E, Doebbeling BN. Incarceration and veterans of the first Gulf War. Military Medicine. 2005;170(7):612-8. [pmid: 16130644].
88 Erickson SK, Rosenheck RA, Trestman RL, Ford JD, Desai RA. Risk of incarceration between cohorts of veterans with and without mental illness discharged from inpatient units. Psychiatric Services (Washington, DC). [doi: 10.1176/appi.ps.59.2.178]. 2008;59(2):178-83.
89 McGuire J, Rosenheck RA, Kasprow WJ. Health status, service use, and costs among veterans receiving outreach services in jail or community settings. Psychiatr Serv. Feb. 2003;54(2):201-7. [pmid: 12556601].
90 Metraux S, Caterina R, Cho R. Incarceration and homelessness. Stephen Metraux. 2008:1-.
91 Samuels P, Mukamal D. After Prison: Roadblocks to Reentry. Legal Action Center. 2004.
92 Pearson J, Davis L. Serving parents who leave prison: final report on the work and family center. Denver, Colorado. Center for Policy Research. 2001.
93 Thoennes N. Child support profile: Massachusetts incarcerated and paroled parents. Denver, Colorado. Center for Policy Research. 2002.
94 Benda BB, Rodell DE, Rodell L. Crime among homeless military veterans who abuse substances. Psychiatr Rehabil J. Spring. 2003;26(4):332-45. [pmid: 12739904].
95 Copeland LA, Miller AL, Welsh DE, McCarthy JF, Zeber JE, Kilbourne AM. Clinical and demographic factors associated with homelessness and incarceration among VA patients with bipolar disorder. Am J Public Health. May. 2009;99(5):871-7. [pmid: 19299667].
96 Stovall JG, Cloninger L, Appleby L. Identifying homeless mentally ill veterans in jail: a preliminary report. J Am Acad Psychiatry Law. 1997;25(3):311-5. [pmid: 9323657].
97 Steadman HJ, Barbera SS, Dennis DL. A National Survey of Jail Diversion Programs for Mentally Ill Detainees. Hosp Community Psychiatry. 1994;45(11):1109-13. [pmid: 7835858].
98 Broner N, Lattimore PK, Cowell AJ, Schlenger WE. Effects of diversion on adults with co-occurring mental illness and substance use: outcomes from a national multi-site study. Behavioral Sciences & the Law. [Article]. 2004;22(4):519-41.
99 Case B, Steadman HJ, Dupuis SA, Morris LS. Who succeeds in jail diversion programs for persons with mental illness? A multi-site study. Behavioral Sciences & the Law. [doi: 10.1002/bsl.883]. 2009;27(5):661-74. [pmid: 19557758].
100 Shafer MS, Arthur B, Franczak MJ. An analysis of post-booking jail diversion programming for persons with co-occurring disorders. Behavioral Sciences & the Law. [doi: 10.1002/bsl.603]. 2004;22(6):771-85. [pmid: 15386559].
101 Sirotich F. The Criminal Justice Outcomes of Jail Diversion Programs for Persons With Mental Illness: A Review of the Evidence. J Am Acad Psychiatry Law. 2009;37(4):461-72. [pmid: 20018995].
102 Steadman HJ, Cocozza JJ, Veysey BM. Comparing outcomes for diverted and nondiverted jail detainees with mental illnesses. Law and Human Behavior. 1999;23(6):615-27. [pmid: 10633579].
103 Steadman HJ, Naples M. Assessing the effectiveness of jail diversion programs for persons with serious mental illness and co-occurring substance use disorders. Behavioral Sciences & the Law. 2005;23(2):163-70. [pmid: 15818607].
104 Wilson DB, Mitchell O, MacKenzie DL. A systematic review of drug court effects on recidivism. Journal of Experimental Criminology. 2006;2(4):459-87.
105 Toomey S. Diversion program for vets is offered. Anchorage Daily News. July. 14. 2004.
106 Russell RT. Veterans Treatment Court: A Proactive Approach. New England Journal on Criminal and Civil Confinement. 2009;35:357-.
107 Hawkins JMD. Coming Home: Accommodating the Special Needs of Military Veterans to the Criminal Justice System. Ohio St J Crim L. 2010;7:563-849.
108 Under Secretary for H. Information and recommendations for services provided by VHA facilities to Veterans in the criminal justice system. 2009.
109 Moral Waivers and the Military. The New York Times. 2007.
110 Schmitt E. Its Recruitment Goals Pressing, the Army Will Ease Some Standards. New York Times. 2004.