# METHODS

## TOPIC DEVELOPMENT

Key questions for this review were developed with the input of experts from the National Center for Homelessness Among Veterans and the VA New England Healthcare System, and with feedback from national experts on homelessness and homelessness among Veterans (see Appendix B).

The final key questions are:

Key Questions | #1a. | What is the prevalence and incidence of homelessness among Veterans?
| #1b. | How has the prevalence and incidence of homelessness among Veterans changed over time?
| #1c. | How prevalent are psychiatric illness, substance abuse, and chronic medical illness among homeless Veterans?
Key Questions | #2a. | Which risk factors are associated with new homelessness or a return to homelessness among Veterans? How do these risk factors differ from non-Veteran populations?
| #2b. | Have risk factors for homelessness among Veterans changed over time?
Key Question | #3. | Are there factors specific to military service that increase the risk of homelessness, or is the increased risk a marker for pre-military comorbidities and social support deficiencies?
Key Question | #4. | What is the relationship between incarceration and homelessness among Veterans?

## SEARCH STRATEGY

To answer these questions, we began with a horizon scan for any studies or reviews of studies about homelessness and Veterans. The search was performed in December 2009 in MEDLINE (coverage: 1947-present) and the Cochrane Database of Systematic Reviews (coverage: 1993-present), with no limitations on publication year. A supplementary search was conducted in Sociological Abstracts (coverage: 1952-present). Searches in those databases covered the literature available from the beginning of their coverage year through December 2009, and were updated to include coverage through July 2010. We also monitored Table of Contents alerts for several publications to indentify new research published in 2010. To answer Key Question #3, we conducted an additional search of several non-medical qualitative journals, including Qualitative Research and Qualitative Health Research, with keyword searches on (homeless) AND (military OR combat OR veteran). To answer Key Question #4, we conducted a broad search of MEDLINE, Sociological Abstracts, and Criminal Justice Abstracts (coverage: 1968-present) to identify any studies or reviews of studies of Veterans and incarceration. Keyword searches were conducted in each database for any articles including ((veteran*) AND (jail OR incarcerat* OR prison*)). In addition, a supplementary search of Google Scholar was conducted, looking for any articles meeting the criteria (allintitle: veteran incarcerate OR incarcerated OR incarceration OR prison OR prisoner OR jail). Google Scholar searches were limited to title words because of the large number of articles returned by a more general keyword search.

We sought additional key sources outside indexed journals from homeless researchers and policy-makers identified through snowball sampling (Appendix B). For all key questions, the reference lists of articles returned were reviewed for any additional relevant studies.

## STUDY SELECTION

Because of the exploratory nature of this review, few restrictions were placed on articles to be considered for inclusion. Abstracts and full-text articles were not dual reviewed for inclusion. The authors each had responsibility for specific key questions, and reviewed abstracts and full-text articles for those key questions to identify any that might have relevance to the topic of prevalence, risk factors, psychiatric disorders, substance abuse, or chronic medical conditions (VC), military and combat related issues (AT), and incarceration and diversion (HB).

## DATA SYNTHESIS

The existing evidence base relevant to this topic does not lend itself to a quantitative synthesis, since sample populations and variables investigated were rarely consistent across studies. In this report, we did not conduct a quantitative data synthesis or meta-analysis, but rather focused on presenting the strength of each existing study’s findings and developing a conceptual model for understanding what these findings mean collectively, as well as indicating where there are significant gaps in our knowledge on this topic.

## CONCEPTUAL MODEL

Based on a preliminary review of the evidence, the authors developed a conceptual model that provided an analytic framework for understanding the connections between risk factors investigated in different studies. Initially focused on the specific risk factors associated with military service, our conceptual model grew to include pre-military risk factors, as well as factors that, in their general definition, are not unique to Veterans (low or unstable income, for example). We constructed a visual model (Figure 1) to help qualitatively identify the experiences and intermediate outcomes that may be relevant in understanding Veteran homelessness. The conceptual model evolved out of our review and is grounded in the available evidence, with those associations supported by more than one study marked by solid lines, while associations shown by only one study, or where existing evidence is inconsistent, indicated by dashed lines.

Figure 1 Risk Factors for Veteran Homelessness: Conceptual Model

A few comments on the assumptions and rationale behind the model are in order. First, several exposures with the same strength of associational evidence are grouped together in one box. This is the case with “low income/low social support/arrests and convictions” and again with all the pre-military service exposures examined. This was done for two reasons: to simplify the model and to graphically suggest that it is likely these exposures interact with one another in ways which are not well isolated or identified in existing research. As is frequently acknowledged in the literature, risk factors for homelessness rarely occur in isolation. Second, the model includes two “black boxes” representing the presence of unmeasured variables. While the primary purpose of the model is to represent what is currently known based on evidence, a secondary purpose of the model is to conceptually make sense of the evidence. Where the mechanism or mediating factors linking two statistically associated variables has not been adequately explored – as, for example, in one study associating Military Sexual Trauma (MST) directly with homelessness – the evidence passes through the black box. In contrast, research investigating low social support, low or unstable income, and arrests/convictions generally makes a clear case for the ways in which these exposures place one at risk for homelessness, and thus no mediating box is included. Third, time is included in the model, which allows the direction of the association to be assumed in some cases (as with early life exposures).

The strength of the associations as indicated in the model is based upon the strength of existing evidence for the Veteran population, but it attempts to indicate how Veteran-specific exposures impact what we have called the “shared exposures,” i.e., those common to the general homeless population in the United States. One strength of this model is that it allows the reader to conceptualize the relationships among risk factors unique to the experience of Veterans together with risk factors common to broader populations of homeless individuals. For example, the association between low social support and homelessness is a general one that has been observed in other homeless populations, as has the association between low social support and mental illness. However, the association between mental illness and combat exposure is unique to Veterans. We feel it may be important for future intervention efforts to understand these Veteran-unique exposures and their impact on shared exposures, and have thus highlighted them in this report, even as we conclude that homeless Veterans have much in common with the non-Veteran homeless.

This conceptual model, though derived independently by the review team and more inclusive of structural risk factors, bears similarities to the model put forward by Rosenheck and Fontana (1994), who looked at data from the National Vietnam Veterans Readjustment Survey (NVVRS) to investigate risk factors for Veteran homelessness.15 The NVVRS was a landmark attempt to understand the impact of the Vietnam War on both the physical and social health of Veterans, and no study to date has replicated its nationally representative, mixed-methods data collection design for investigating multiple risk factors. The current generation of Veterans who have experienced the conflicts in Iraq and Afghanistan may exhibit different characteristics and is deserving of research of similar scope.

## PEER REVIEW

A draft version of this report was reviewed by six experts in the field of homelessness. Their comments and our responses are presented in Appendix A.