# TECHNICAL EXPERTS CONSULTED AND REVIEWERS

## TECHNICAL EXPERTS CONSULTED

Ted Amann

Director of Homeless Programs

Central City Concern

Portland, Oregon

Monica Beemer

Executive Director

Sisters of the Road

Portland, Oregon

Lillian Gelberg, M.D., MSPH

Professor of Family Medicine

UCLA Geffen School of Medicine

Los Angeles, California

Don Miller

Chief Counsel

Housing and Urban Development

Portland, Oregon

Fran Randolph

Director of the Division of Services and Systems Improvement

SAMHSA, Center for Mental Health Services

Jim Reuler, M.D.

Professor, Department of Medicine

Oregon Health and Science University

Portland, Oregon

Robert Rosenheck, M.D.

Director, Northeast Program Evaluation Center and

Professor of Psychiatry and Public Health

Yale University School of Medicine

New Haven, Connecticut

Annetta C. Smith

Population Division

U.S. Census Bureau

## REVIEWERS

Mary K. Cunningham

Senior Research Associate

Urban Institute

Amy Kilbourne, Ph.D., MPH

VA Serious Mental Illness Treatment Resource and Evaluation Center

John Kuhn

National CHALENG Coordinator

Stephen Metraux, Ph.D.

National Center for Homelessness Among Veterans

Thomas O’Toole, M.D.

Providence VA Medical Center

David Smelson, Psy.D.

Bedford VA Medical Center