# RESULTS

We reviewed 11,321 titles and abstracts, including 10,996 from the electronic search and an additional 325 from reviewing reference lists and performing manual searches for recently published and unpublished or ongoing studies (Appendix B, Figure 2). After applying inclusion/exclusion criteria at the abstract level, 264 full-text articles were reviewed. Thirty-five primary studies contained primary data relevant to the efficacy of HCC screening or treatment of early-stage HCC and met our inclusion criteria. We also included 2 systematic reviews of providing evidence on harms of treatment modalities.26,27

## EFFECTS OF SCREENING ON MORTALITY

Two trials and 16 observational studies provided very low strength evidence from which to draw conclusions about the mortality effects of HCC screening compared to no screening. The trials had substantial methodologic flaws that threaten their internal validity, and their applicability was limited to the hepatitis B population. The observational studies, which mainly included patients with HBV, HCV, and/or alcoholic liver disease, showed that screening detects patients with earlier stage disease, more of whom undergo potentially curative therapy. However, it is impossible to say whether the longer survival in screen-detected patients is a true effect of screening or, rather, reflects lead- and length-time biases inherent to all observational studies, and selection biases which were common in many of the studies.

### Effects of screening on mortality: Randomized controlled trials

Two trials, both conducted in China, compared the effects of screening to no screening on mortality among participants mainly with hepatitis B (Appendix D, Table 1).28,29 One trial used a cluster-randomized design to assign factories, business, and schools to screening or no screening groups. Screening group participants (n = 9,757) were offered serum AFP testing and ultrasonography every 6 months. The control group (n = 9,443) was not made aware of the study or actively followed. Information on HCC development and mortality was based on physician reporting and a cancer registry, though there were no details reported about registry development. The primary outcome of HCC mortality occurred less frequently in the screening group (83.2/100,000 person-years vs 131.5/100,000 person-years; rate ratio 0.63, 95% CI 0.41-0.98).

The trial, however, carries a high risk of bias because of several serious methodological limitations (Appendix D, Table 2). One major concern is whether the baseline groups had the same risk of HCC. There is no information about randomization technique or allocation concealment, and very little information about the baseline characteristics of the 2 groups. In cluster-randomized trials, in which patients are assigned to treatments based on where they live or work, it is important to know whether the underlying populations are similar in socioeconomic status, the incidence of other diseases, and overall mortality. Another concern is that weak methods used to ascertain the outcome measure – death from HCC – could have introduced bias. Outcome ascertainment depended on physician report, but there was no systematic effort described to ensure complete and equal outcome reporting nor was there any information about the cancer registry or about the proportion of patients for whom survival data was available. If deaths were under-reported in the control group, results could have been biased towards the null. On the other hand, if outcome adjudicators were not blinded, more control group deaths could have been misclassified as HCC-related, especially because the symptoms that define stage III HCC (cachexia, jaundice, ascites) overlap substantially with symptoms of end-stage liver disease and there was no data provided about liver disease severity in either group. Selective reporting and analysis of favorable outcomes was another concern. Though the authors report that vital status was available for all patients, overall mortality was not reported, and there was no statistical adjustment for the effects of clustering. Finally, the study is less applicable to the US wherein cirrhosis, most often from hepatitis C, is the most common risk factor for HCC, and there is probably limited applicability for these results to contemporary practice, in which the threshold for imaging for symptoms may be lower and the number of patients with incidentally-discovered HCC on imaging is higher.

The second trial used patient-level randomization stratified by township to assign hepatitis B patients to the screening intervention (n = 3,712), which consisted of serial AFP tests followed by ultrasound for high AFP values, or the usual care group (n = 1,869).29 Cancer diagnoses were available in a population-based cancer registry which used active case finding techniques, and mortality was ascertained through the cancer registry and a population-based vital status registry. Cancer staging using the same Chinese staging system was done by personnel blinded to intervention status. Only 28.8% of screening-group participants completed all scheduled testing, but all participants completed at least one screening test. There were fewer Stage III HCC in the screening group (19.8 vs 41.0%, p = NR). HCC mortality was similar in both groups (1,138/100,000 person-years vs 1114/100,000 person-years, p = 0.86), as was all-cause mortality (1,843/100,000 person-years vs 1,788/100,000 person-years, p = NS). This trial carried an unclear risk of bias because of poor reporting of randomization and allocation concealment techniques.

Two additional trials compared different ultrasound screening intervals.30,31 One found no survival advantage comparing 4-month to 12-month ultrasound screening intervals in patients with serologic evidence of hepatitis B or C.30 About one-third of patients in both groups had liver cirrhosis. Systematic ultrasound exams were performed by trained hepatologists and all patients with new nodules ≥ 1 cm were referred for further follow-up. More patients in the 4-month interval group had new liver nodules (11.9 vs 7.8%, p = 0.049), but the 3-year cumulative incidence of HCC was similar in both groups (11.7 vs 9.7%, p = 0.198). Although screening every 4 months identified more patients with ≤ 2 cm HCC (70.8 vs 20.0%, p = 0.006) and more patients with HCC in the 4-month interval group underwent resection or radiofrequency ablation treatment (54.2 vs 20%, p = 0.049), the 1-, 2-, and 4-year survival rates among patients with HCC were similar (95.8/78.8/57.4% vs 80/64/56%, p = 0.399). The trial used clustered randomization and carried an unclear risk of bias because of poor reporting of outcome assessment and statistical analyses.

A trial with low risk-of-bias compared 3-month to 6-month ultrasound screening intervals in 1,278 patients with cirrhosis from alcohol use and/or viral hepatitis and found similar all-cause mortality rates in both groups (11.3 vs 12.1%, p = 0.38).31 A similar number of patients were diagnosed with HCC in both groups (8.3 vs 11.0%, p = 0.13), and most met Milan criteria (79.2 vs 71.4%, p = 0.40).

### Effects of screening on mortality: Observational studies

We included 16 observational studies which compared survival in patients with HCC diagnosed with screening to HCC diagnosed incidentally as part of another work-up or because of symptoms (Appendix D, Table 3).32-47

Studies represented a range of geographic settings including Asia (6 studies), Europe (5 studies), Australia (1 study), and the US (4 studies, of which 3 were conducted in the VA). The vast majority of patients included in these studies had hepatitis B or C with Child-Pugh class A or B cirrhosis, though in many studies, liver disease severity was significantly higher in the non-screening groups. Ultrasound with or without AFP measurement was the screening method used in nearly all studies, except for 2 US studies in which a small number of patients underwent CT.34,39

In general, patients who had undergone screening had earlier stage HCC than those who had HCC diagnosed incidentally or due to symptoms (% range meeting equivalent of Milan criteria: 60.0-100 vs 19.6-56.5 in 10 studies). More screen-detected patients received potentially curative treatment, though only a small proportion of screening group patients underwent hepatic resection (range 2.8-23.9% in 12 studies,32,34,36-39,41-46 and 53.5% in one outlier study47) or liver transplantation (1-15% in 5 studies,36,39,40,44,46 and 26-30.1% in 2 other studies).32,43 Survival from the time of HCC diagnosis was generally higher among screening group patients than non-screening group patients (Appendix D, Table 3). Median survival ranged among studies from 12-56 months in the screening group, and from 3-37 months in the non-screening group (Appendix B, Figure 3). Three-year survival ranged from 22-67% in the screening group, and from 15-51 percent in the non-screening group. Unadjusted mortality risk was significantly lower in the screening group in some studies35,38,39,47 although this survival advantage was not statistically significant in one study.33

Three of the observational studies reported objective and replicable methods for distinguishing screening from non-screening patients, and had comparatively fewer issues with selection bias by drawing patients from the VA – a single, large integrated health system.34,35,39 The largest of these used the national VA HCV clinical case registry to identify 1,480 HCC patients, and was the only study to assess survival from the time at-risk for HCC (in this case, the HCV diagnosis date), rather than from the date of HCC diagnosis.35 Patients who had had screening done both 0-6 months and 7-24 months prior to HCC diagnosis had modestly longer survival than those with no screening (median survival from HCV diagnosis 1,951 vs 1,782 days; HR=0.82; 95% CI: 0.72-0.95). Those with screening in either, but not both, time periods had similar survival as those with no screening. In models adjusted for lead-time, the survival advantage of recurrent screening was attenuated with longer lead-time assumptions. The other 2 studies were also conducted in VA and included patients with HCV and HCC. One of the studies found that screening was not associated with improved survival, but rates of screening were low and cited as a possible reason for the lack of observed survival effect.34 The other study found HCC screening was not associated with improved survival, though receipt of potentially curative therapy was associated with improved survival.39

Overall, there are several methodologic considerations which temper the confidence with which one can draw conclusions from the body of observational literature (Appendix D, Table 4). Most of the studies were single center retrospective cohort studies in which all patients with diagnosed HCC were first identified and screening status was subsequently determined. Few studies reported data about loss to follow-up, and many studies did not report using a comprehensive method to assess mortality outcomes equally in screening and non-screening groups. In most studies, the comparison group was drawn from a referral population and there are likely unmeasured patient, treatment, health care access and other factors that are different between groups. Even in the VHA studies in which all patients are part of the same health system, most screen-detected patients were followed by hepatologists and it is possible that co-interventions unrelated to HCC treatment differed between groups.

In addition to the methodologic issues specific to individual studies detailed in Appendix D, Tables 2 and 4, the potential for lead-time bias, in which the “lead-time” between cancer diagnosis in screened and unscreened groups adds to the apparent survival advantage, is inherent in any observational study of screening effects.48 Though there is no infallible way to circumvent the threat of lead-time bias other than the conduct of a well-designed RCT, 4 studies used statistical techniques to adjust for lead-time bias.35,41,43,46 These studies used various assumptions about tumor doubling time to estimate the lead-time of screening diagnosis. Three of the studies adjusted for lead-time and found the survival advantage for screening patients disappeared when the tumor doubling time was assumed to be 90-120 days or longer.35,41,46 A fourth study used serial ultrasound data from 13 patients to estimate a tumor doubling time of 216 days, though survival among screening patients remained higher even after adjusting for lead-time.43

Of note, length-time bias, in which screening identifies patients with slower growing tumors, may complicate lead-time estimates.

## HARMS OF SCREENING

Potential harms of screening can relate to the physical effects of the screening tests themselves, to testing triggered by a positive screening test, or to the psychologic effects of having a positive screening test. None of the included studies reported harms of screening, but the direct physical harms of HCC screening using ultrasound and/or AFP – which were the most commonly studied screening modalities - are likely to be minimal. However, most patients with positive screening ultrasound and/or AFP undergo further confirmatory testing. In most of the studies, confirmatory testing was done with CT and, less commonly, with MRI or liver biopsy, though very few studies reported rates of actual testing used for diagnosis. In 2 studies, HCC diagnosis was based on biopsy in 33-80.3% of cases.32,39 One meta-analysis of 8 studies found the risk of needle track seeding from liver biopsy done for work-up of HCC to be 2.7%.26 One single-center study published after this meta-analysis found 0.12% of patients experienced needle track seeding.49 One recent systematic review of the diagnostic accuracy of imaging for HCC screening and diagnosis found very few studies reporting harms data: one study found contrast-enhanced CT was associated with adverse events in 13-15% of patients, while another found mild-moderate adverse events in 25% patients receiving gadoxetic acid-enhanced MRI.50 We found no studies evaluating the psychologic harms of screening.

## HCC SCREENING IN VHA

Three observational studies, all comparing outcomes in patients with screen-detected HCC to those incidentally diagnosed, were conducted in the VHA; the results are summarized above.34,35,39 The bulk of the remaining screening literature is less directly applicable to VA, where HCV cirrhosis is the major risk factor for HCC. The screening trials included only patients with HBV. While many of the remaining observational studies included subgroups with HCV, subgroup-specific data were not available (Appendix D, Table 3).

Studies suggest the practice of HCC screening in VA is inconsistent. The VA HCV Clinical Case Registry study of 1480 HCV-infected patients with HCC found that, though the vast majority had received one AFP test (89%) or ultrasound exam (78%) between HCV and HCC diagnoses, only 21.2% of the ultrasounds were classified as screening tests and about one-third of patients (34.4%) had received annual testing in the 2 years prior to HCC diagnosis.35 The other 2 VA studies examined patients at 1-3 VA centers and similarly found low rates of routine screening.34,39

Another VHA HCV Clinical Case Registry study examining screening practices found that, of the 10.1% of HCV-infected Veterans with cirrhosis, 42% received at least one screening US or AFP test in the first year after diagnosis of cirrhosis.51 However, an additional 30% of these patients had had one of these tests done for reasons other than screening in the same time frame. Rates of screening declined in each year after cirrhosis diagnosis, and several clinical factors such as higher comorbidity burden, more advanced liver disease, and higher rates of alcohol use were associated with lower use of screening. On the other hand, nearly 30% of HCV patients without cirrhosis received a screening test the year following HCV diagnosis.

In contrast to the inconsistent observed use of screening in VHA, a majority (71%) of VHA providers reported recommending HCC screening in a recent survey.52 Providers specializing in the care of patients with liver disease, and those practicing at centers where HCC treatment was readily available were more likely to report recommending HCC screening.

## EFFECTS OF TREATING HCC DETECTED AS A RESULT OF SCREENING

No studies specifically enrolled patients with screen-detected HCC, so we examined studies of patients with early-stage HCC as a way of approximating screen-detected disease. Overall, there is little evidence with which to draw conclusions about the net benefits of actively treating early-stage HCC compared to conservative treatment. The few trials comparing active to conservative treatment of early stage HCC examined TACE. Observational studies do show that patients selected for treatment with OLT, resection, or RFA had good long-term survival, which was substantially higher than patients not selected for such therapy, but it is unclear whether such effects reflect a true effect of treatment or reflect confounding by indication.

Three clinical trials that included patients with early-stage HCC compared TACE to conservative treatment, but these studies were limited by small sample size and lack of subgroup information specific to patients with early-stage disease (Appendix D, Tables 5-6). Low strength evidence from 2 trials found no survival benefit from TACE in patients with alcoholic liver disease. One of these was a multicenter trial with low risk of bias which was stopped early for futility after enrolling 96 patients,53 and the other was a smaller study with unclear risk of bias of 42 patients in France.54 Low strength evidence from one trial with unclear risk of bias, about half of whom had early-stage HCC, found TACE was associated with improved survival in HBV patients (RR 0.49; 95% CI 0.29-0.81).55 We excluded a fourth trial because it included only patients with advanced HCC.56

Low strength evidence from one large cohort study of patients with early-stage HCC found lower mortality among those that had undergone resection compared to those treated conservatively, after adjusting for tumor size and basic demographic characteristics (adjusted HR 0.45; 95% CI 0.34-0.59, p < 0.01).57 The 4 other comparative observational studies were difficult to interpret because they compared more than one treatment across heterogeneous groups of patients with early- and late-stage disease (Appendix D, Tables 7-8). However, many patients selected for treatment had good long-term (4- or 5-year) survival: 53-73% for OLT,58-61 33-75% for resection,57,62 and 27-77% for RFA.58,62-64

## HARMS ASSOCIATED WITH TREATMENT OF EARLY-STAGE HCC

Serious harms occurred in 1.8-20% of patients, depending on the intervention (Appendix D, Tables 5, 7, and 9). Across the 3 trials examining the effects of TACE, 8-20% of patients experienced serious treatment related complications though it is unclear what proportion of these patients had early- versus late-stage disease. A systematic review of 23 studies found an aggregate perioperative mortality rate among 3,366 patients undergoing resection of 4%.27

One single-center cohort study of 1,031 consecutive patients found 3.2% of patients developed needle-track seeding after undergoing RFA for HCC.65 Two single-center cohort studies found serious complications in 1.8-9.9% of patients including peritoneal bleeding, hemothorax, and portal vein thrombosis.63,66 Harms of OLT were not well-reported.

## CURRENT HCC SCREENING GUIDELINES

We found 26 guidelines addressing HCC screening. We focused on the 3 most widely disseminated guidelines representing North America, Europe, and Asia (see Appendix D, Table 10 for a summary of the screening recommendations from the 3 guidelines). All 3 recommend that those at high risk for HCC should be routinely screened every 6 months by US (AASLD & EASL)8,9 or by US and AFP (APASL).10 The 3 guidelines provide different specific recommendations about high risk groups and screening schedules based on initially positive screening results. We critically appraised the guidelines using the AGREE II framework and identified several methodological flaws (Appendix D, Table 11 describes the AGREE II ratings for each guideline). None of the guidelines reported a systematic review of the literature and none reported critically appraising included studies to assess their internal validity. The guidelines lacked a description of the strengths and weaknesses of the overall body of evidence and, rather, cited levels of evidence based simply on study design (Level I evidence based on RCT in the case AASLD, level 2a evidence based on consistent evidence from cohort studies in the case of APASL) or did not define the level of evidence (EASL). Each of the guidelines cited the Zhang 2004 trial as the major source of evidence supporting recommendations, though, as we describe above, the methodologic flaws of this trial and many of the observational studies limit their internal validity which, in turn, weakens the strength of evidence.