# REFERENCES

1 Jemal A, Simard EP, Dorell C, et al. Annual Report to the Nation on the Status of Cancer, 1975-2009, featuring the burden and trends in human papillomavirus(HPV)-associated cancers and HPV vaccination coverage levels. Journal of the National Cancer Institute. Feb. 6. 2013;105(3):175-201. [pmid: 23297039].
2 Siegel R, Naishadham D, Jemal A. Cancer statistics, 2012. CA Cancer J Clin. Jan-Feb. 2012;62(1):10-29. [pmid: 22237781].
3 But DY, Lai CL, Yuen MF. Natural history of hepatitis-related hepatocellular carcinoma. World J Gastroenterol. Mar. 21. 2008;14(11):1652-1656. [pmid: 18350595].
4 Kanwal F, Hoang T, Kramer JR, et al. Increasing prevalence of HCC and cirrhosis in patients with chronic hepatitis C virus infection. Gastroenterology. Apr. 2011;140(4):1182-1188.e1181. [pmid: 21184757].
5 Altekruse SF, McGlynn KA, Reichman ME. Hepatocellular carcinoma incidence, mortality, and survival trends in the United States from 1975 to 2005. Journal of Clinical Oncology. Mar. 20. 2009;27(9):1485-1491. [pmid: 19224838].
6 Howlader N, Noone AM, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2010. National Cancer Institute. Bethesda, MD. http://seer.cancer.gov/csr/1975_2010/, based on November 2012 SEER data submission, posted to the SEER web site 2013. http://seer.cancer.gov/statfacts/html/livibd.html#incidence-mortality.
7 Singal A, Volk ML, Waljee A, et al. Meta-analysis: surveillance with ultrasound for early-stage hepatocellular carcinoma in patients with cirrhosis. Alimentary Pharmacology & Therapeutics. Jul. 2009;30(1):37-47. [pmid: 19392863].
8 Bruix J, Sherman M, American Association for the Study of Liver D. Management of hepatocellular carcinoma: an update. Hepatology. Mar. 2011;53(3):1020-1022. [pmid: 21374666].
9 Llovet JM, Ducreux M, Lencioni R, et al. EASL-EORTC Clinical Practice Guidelines: Management of hepatocellular carcinoma. European Journal of Cancer. 2012;48(5):599-641. [pmid: 22424278].
10 Omata M, Lesmana LA, Tateishi R, et al. Asian pacific association for the study of the liver consensus recommendations on hepatocellular carcinoma. Hepatology International. 2010;4(2):439-474. [pmid: 20827404].
11 Lederle FA, Pocha C. Screening for liver cancer: the rush to judgment. Ann Intern Med. Mar. 6. 2012;156(5):387-389. [pmid: 22393134].
12 Bleyer A, Welch HG. Effect of three decades of screening mammography on breast-cancer incidence. New England Journal of Medicine. Nov. 22. 2012;367(21):1998-2005. [pmid: 23171096].
13 Etzioni R, Penson DF, Legler JM, et al. Overdiagnosis due to prostate-specific antigen screening: lessons from U.S. prostate cancer incidence trends. Journal of the National Cancer Institute. Jul. 3. 2002;94(13):981-990. [pmid: 12096083].
14 Aghoram R, Cai P, Dickinson JA. Alpha-foetoprotein and/or liver ultrasonography for screening of hepatocellular carcinoma in patients with chronic hepatitis B. Cochrane Database Syst Rev. 2012;(9):CD002799. [pmid: 22972059].
15 Sherman M, Bruix J, Porayko M, Tran T. Screening for hepatocellular carcinoma: The rationale for the American Association for the Study of Liver Diseases recommendations. Hepatology. 2012;56(3):793-796. [pmid: 22689409].
16 HSR&D. ESP Reports in Progress. http://www.hsrd.research.va.gov/publications/esp/in_progress.cfm.
17 Treadwell J, Reston J, Singh S, Talati R, McPheeters M. A Framework for “Best Evidence” Approaches in Systematic Reviews. Methods Research Report. (Prepared by the ECRI Institute Evidence-based Practice Center under Contract No. HHSA 290-2007-10063-I.) AHRQ Publication No. 11-EHC046-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.June.
18 Bruix J, Llovet JM. Prognostic prediction and treatment strategy in hepatocellular carcinoma. Hepatology. Mar. 2002;35(3):519-524. [pmid: 11870363].
19 Mazzaferro V, Regalia E, Doci R, et al. Liver transplantation for the treatment of small hepatocellular carcinomas in patients with cirrhosis. New England Journal of Medicine. Mar. 14. 1996;334(11):693-699. [pmid: 8594428].
20 Higgins JPT, Green S, editors. Part 2, Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. 2008;Version 5.10. The Cochrane Collaboration. 2008. Updated March 2011. www.cochrane-handbook.org. June 12, 2013.
21 Guyatt GH, Oxman AD, Schunemann HJ, Tugwell P, Knottnerus A. GRADE guidelines: a new series of articles in the Journal of Clinical Epidemiology. Journal of Clinical Epidemiology. Apr. 2011;64(4):380-382. [pmid: 21185693].
22 Viswanathan M, Mohammed A, Berkman N, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). Agency for Healthcare Research and Quality (US). 2012. [pmid: 22479713].
23 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):1-173. [pmid: 14499048].
24 Patient-Centered Outcomes Research Institute. PCORI Methodology Standards. December. 14. 2012.
25 The AGREE Next Steps Consortium. Appraisal of Guidelines for Research & Evaluation II (AGREE II) Instrument. May. 2009. www.agreetrust.org.
26 Silva MA, Hegab B, Hyde C, Guo B, Buckels JAC, Mirza DF. Needle track seeding following biopsy of liver lesions in the diagnosis of hepatocellular cancer: a systematic review and meta-analysis. Gut. Nov. 2008;57(11):1592-1596. [pmid: 18669577].
27 Asiyanbola B, Chang D, Gleisner AL, et al. Operative mortality after hepatic resection: are literature-based rates broadly applicable?. J Gastrointest Surg. May. 2008;12(5):842-851. [pmid: 18266046].
28 Zhang BH, Yang BH, Tang ZY. Randomized controlled trial of screening for hepatocellular carcinoma. J Cancer Res Clin Oncol. Jul. 2004;130(7):417-422. [pmid: 15042359].
29 Chen JG, Parkin DM, Chen QG, et al. Screening for liver cancer: results of a randomised controlled trial in Qidong, China. J Med Screen. 2003;10(4):204-209. [pmid: 14738659].
30 Wang JH, Chang KC, Kee KM, et al. Hepatocellular Carcinoma Surveillance at 4- vs. 12-Month Intervals for Patients With Chronic Viral Hepatitis: A Randomized Study in Community. Am J Gastroenterol. Jan. 15. 2013.
31 Trinchet JC, Chaffaut C, Bourcier V, et al. Ultrasonographic surveillance of hepatocellular carcinoma in cirrhosis: a randomized trial comparing 3- and 6-month periodicities. Hepatology. Dec. 2011;54(6):1987-1997. [pmid: 22144108].
32 Bolondi L, Sofia S, Siringo S, et al. Surveillance programme of cirrhotic patients for early diagnosis and treatment of hepatocellular carcinoma: a cost effectiveness analysis. Gut. Feb. 2001;48(2):251-259. [pmid: 11156649].
33 Chen TH, Chen CJ, Yen MF, et al. Ultrasound screening and risk factors for death from hepatocellular carcinoma in a high risk group in Taiwan. Int J Cancer. Mar. 10. 2002;98(2):257-261. [pmid: 11857416].
34 Davila JA, Weston A, Smalley W, El-Serag HB. Utilization of screening for hepatocellular carcinoma in the United States. J Clin Gastroenterol. Sep. 2007;41(8):777-782. [pmid: 17700427].
35 El-Serag HB, Kramer JR, Chen GJ, Duan Z, Richardson PA, Davila JA. Effectiveness of AFP and ultrasound tests on hepatocellular carcinoma mortality in HCV-infected patients in the USA. Gut. Jul. 2011;60(7):992-997. [pmid: 21257990].
36 Giannini E, Arzani L, Borro P, et al. Does surveillance for hepatocellular carcinoma in HCV cirrhotic patients improve treatment outcome mainly due to better clinical status at diagnosis?. Hepatogastroenterology. Sep-Oct. 2000;47(35):1395-1398. [pmid: 11100360].
37 Kemp W, Pianko S, Nguyen S, Bailey MJ, Roberts SK. Survival in hepatocellular carcinoma: impact of screening and etiology of liver disease. J Gastroenterol Hepatol. Jun. 2005;20(6):873-881. [pmid: 15946134].
38 Kuo YH, Lu SN, Chen CL, et al. Hepatocellular carcinoma surveillance and appropriate treatment options improve survival for patients with liver cirrhosis. Eur J Cancer. Mar. 2010;46(4):744-751. [pmid: 20060710].
39 Leykum LK, El-Serag HB, Cornell J, Papadopoulos KP. Screening for hepatocellular carcinoma among veterans with hepatitis C on disease stage, treatment received, and survival. Clin Gastroenterol Hepatol. Apr. 2007;5(4):508-512. [pmid: 17382601].
40 Pascual S, Irurzun J, Zapater P, et al. Usefulness of surveillance programmes for early diagnosis of hepatocellular carcinoma in clinical practice. Liver International. 2008;28(5):682-689. [pmid: 18433394].
41 Tanaka H, Nouso K, Kobashi H, et al. Surveillance of hepatocellular carcinoma in patients with hepatitis C virus infection may improve patient survival. Liver Int. Jun. 2006;26(5):543-551. [pmid: 16761998].
42 Taura N, Hamasaki K, Nakao K, et al. Clinical benefits of hepatocellular carcinoma surveillance: a single-center, hospital-based study. Oncol Rep. Oct. 2005;14(4):999-1003. [pmid: 16142364].
43 Tong MJ, Sun HE, Hsien C, Lu DS. Surveillance for hepatocellular carcinoma improves survival in Asian-American patients with hepatitis B: results from a community-based clinic. Dig Dis Sci. Mar. 2010;55(3):826-835. [pmid: 19960258].
44 Trevisani F, De NS, Rapaccini G, et al. Semiannual and annual surveillance of cirrhotic patients for hepatocellular carcinoma: effects on cancer stage and patient survival (Italian experience). Am J Gastroenterol. Mar. 2002;97(3):734-744. [pmid: 11922571].
45 Trevisani F, Cantarini MC, Labate AM, et al. Surveillance for hepatocellular carcinoma in elderly Italian patients with cirrhosis: effects on cancer staging and patient survival. Am J Gastroenterol. Aug. 2004;99(8):1470-1476. [pmid: 15307862].
46 Wong GLH, Wong VWS, Tan GM, et al. Surveillance programme for hepatocellular carcinoma improves the survival of patients with chronic viral hepatitis. Liver International. 2008;28(1):79-87. [pmid: 17900247].
47 Yu EW, Chie WC, Chen TH. Does screening or surveillance for primary hepatocellular carcinoma with ultrasonography improve the prognosis of patients?. Cancer J. Sep-Oct. 2004;10(5):317-325. [pmid: 15530261].
48 Fletcher RH, Fletcher SW, Wagner EH. Clinical epidemiology. The essentials. 2nd ed. Baltimore. Williams and Wilkins. 1988.
49 Ahn DW, Shim JH, Yoon JH, et al. Treatment and clinical outcome of needle-track seeding from hepatocellular carcinoma. Korean J Hepatol. Jun. 2011;17(2):106-112. [pmid: 21757981].
50 Chou R, Cottrell EB, Wasson N, Rahman B, Guise JM. Screening for Hepatitis C Virus Infection in Adults. Comparative Effectiveness Review No. 69. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 12(13)-EHC090-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
51 Davila JA, Henderson L, Kramer JR, et al. Utilization of surveillance for hepatocellular carcinoma among hepatitis C virus-infected veterans in the United States. Annals of Internal Medicine. 2011;154(2):85-93. [pmid: 21242365].
52 El-Serag HB, Alsarraj A, Richardson P, et al. Hepatocellular carcinoma screening practices in the Department of Veterans Affairs: findings from a national facility survey. Digestive Diseases & Sciences. Nov. 2013;58(11):3117-3126. [pmid: 23868438].
53 Groupe d'Etude et de Traitment du Carcinome Hepatocellulaire. A comparison of lipiodol chemoembolization and conservative treatment for unresectable hepatocellular carcinoma. Groupe d'Etude et de Traitement du Carcinome Hepatocellulaire. N Engl J Med. May. 11. 1995;332(19):1256-1261. [pmid: 7708069].
54 Pelletier G, Roche A, Ink O, et al. A randomized trial of hepatic arterial chemoembolization in patients with unresectable hepatocellular carcinoma. J Hepatol. Sep. 1990;11(2):181-184. [pmid: 2174933].
55 Lo CM, Ngan H, Tso WK, et al. Randomized controlled trial of transarterial lipiodol chemoembolization for unresectable hepatocellular carcinoma. Hepatology. May. 2002;35(5):1164-1171. [pmid: 11981766].
56 Llovet JM, Real MI, Montana X, et al. Arterial embolisation or chemoembolisation versus symptomatic treatment in patients with unresectable hepatocellular carcinoma: a randomised controlled trial. Lancet. May. 18. 2002;359(9319):1734-1739. [pmid: 12049862].
57 Liu JH, Chen PW, Asch SM, Busuttil RW, Ko CY. Surgery for hepatocellular carcinoma: does it improve survival?. Ann Surg Oncol. Mar. 2004;11(3):298-303. [pmid: 14993025].
58 Tong MJ, Chavalitdhamrong D, Lu DS, et al. Survival in Asian Americans after treatments for hepatocellular carcinoma: a seven-year experience at UCLA. J Clin Gastroenterol. Mar. 2010;44(3):e63-70. [pmid: 19745756].
59 Onaca N, Davis GL, Jennings LW, Goldstein RM, Klintmalm GB. Improved results of transplantation for hepatocellular carcinoma: a report from the International Registry of Hepatic Tumors in Liver Transplantation. Liver Transpl. Jun. 2009;15(6):574-580. [pmid: 19479800].
60 Burra P, Germani G, Adam R, et al. Liver transplantation for HBV-related cirrhosis in Europe: an ELTR study on evolution and outcomes. J Hepatol. Feb. 2013;58(2):287-296. [pmid: 23099188].
61 Ioannou GN, Perkins JD, Carithers RL Jr. Liver transplantation for hepatocellular carcinoma: impact of the MELD allocation system and predictors of survival. Gastroenterology. May. 2008;134(5):1342-1351. [pmid: 18471511].
62 Lee SS, Shin HS, Kim HJ, et al. Analysis of prognostic factors and 5-year survival rate in patients with hepatocellular carcinoma: a single-center experience. Korean J Hepatol. Mar. 2012;18(1):48-55. [pmid: 22511903].
63 Livraghi T, Meloni F, Di Stasi M, et al. Sustained complete response and complications rates after radiofrequency ablation of very early hepatocellular carcinoma in cirrhosis: Is resection still the treatment of choice?. Hepatology. Jan. 2008;47(1):82-89. [pmid: 18008357].
64 DuBay DA, Sandroussi C, Kachura JR, et al. Radiofrequency ablation of hepatocellular carcinoma as a bridge to liver transplantation. HPB (Oxford). Jan. 2011;13(1):24-32. [pmid: 21159100].
65 Imamura J, Tateishi R, Shiina S, et al. Neoplastic seeding after radiofrequency ablation for hepatocellular carcinoma. Am J Gastroenterol. Dec. 2008;103(12):3057-3062. [pmid: 19086957].
66 Chen WT, Fernandes ML, Lin CC, Lin SM. Delay in treatment of early-stage hepatocellular carcinoma using radiofrequency ablation may impact survival of cirrhotic patients in a surveillance program. Journal of Surgical Oncology. 2011;103(2):133-139. [pmid: 21259246].
67 Cottone M, Virdone R, Fusco G, et al. Asymptomatic hepatocellular carcinoma in Child's A cirrhosis. A comparison of natural history and surgical treatment. Gastroenterology. Jun. 1989;96(6):1566-1571. [pmid: 2469617].
68 Ebara M, Ohto M, Shinagawa T, et al. Natural history of minute hepatocellular carcinoma smaller than three centimeters complicating cirrhosis. A study in 22 patients. Gastroenterology. Feb. 1986;90(2):289-298. [pmid: 2416627].
69 Sheu JC, Sung JL, Chen DS, et al. Growth rate of asymptomatic hepatocellular carcinoma and its clinical implications. Aug. 1985;89(2):259-266.
70 Barbara L, Benzi G, Gaiani S, et al. Natural history of small untreated hepatocellular carcinoma in cirrhosis: a multivariate analysis of prognostic factors of tumor growth rate and patient survival. Hepatology. Jul. 1992;16(1):132-137. [pmid: 1352268].
71 Llovet JM, Bustamante J, Castells A, et al. Natural history of untreated nonsurgical hepatocellular carcinoma: rationale for the design and evaluation of therapeutic trials. Hepatology. Jan. 1999;29(1):62-67. [pmid: 9862851].
72 Chou R. Imaging Techniques for the Surveillance, Diagnosis, and Staging of Hepatocellular Carcinoma. Evidence-based Practice Center Systematic Review Protocol. AHRQ Effective Health Care Program. http://effectivehealthcare.ahrq.gov/ehc/products/479/1600/Liver-cancer-protocol-130724.pdf.
73 Rahman A, Assifi MM, Pedroso FE, et al. Is resection equivalent to transplantation for early cirrhotic patients with hepatocellular carcinoma? A meta-analysis. J Gastrointest Surg. Oct. 2012;16(10):1897-1909. [pmid: 22836922].
74 Kanwal F, Befeler A, Chari RS, et al. Potentially curative treatment in patients with hepatocellular cancer--results from the liver cancer research network. Alimentary Pharmacology & Therapeutics. Aug. 2012;36(3):257-265. [pmid: 22670798].
75 Schlansky B, Chen Y, Austin D, Naugler WE. Wait list time predicts survival after liver transplantation for hepatocellular carcinoma: a cohort study in the UNOS registry. Hepatology. 2013;58(4 (Suppl) AASLD Abstracts):208A.
76 Cabibbo G, Enea M, Attanasio M, Bruix J, Craxi A, Camma C. A meta-analysis of survival rates of untreated patients in randomized clinical trials of hepatocellular carcinoma. Hepatology. Apr. 2010;51(4):1274-1283. [pmid: 20112254].
77 Simonetti RG, Liberati A, Angiolini C, Pagliaro L. Treatment of hepatocellular carcinoma: a systematic review of randomized controlled trials. Annals of Oncology. Feb. 1997;8(2):117-136. [pmid: 9093719].
78 Guyatt GH, Norris SL, Schulman S, et al. Methodology for the development of antithrombotic therapy and prevention of thrombosis guidelines: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):53S-70S. [pmid: 22315256].
79 Moher D, Pham B, Lawson ML, Klassen TP. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health Technology Assessment (Winchester, England). 2003;7(41):1-90.
80 Farinati F, Giacomin A, Vanin V, et al. Liver transplantation for hepatocellular carcinoma in clinical practice: the lesson from a 20-year multicentre experience in Italy. Eur J Gastroenterol Hepatol. Feb. 2012;24(2):195-202. [pmid: 22108511].
81 Mahady SE, Charlton B, Fitzgerald P, et al. Locoregional therapies for hepatocellular carcinoma: which patients are most likely to gain a survival advantage?. J Gastroenterol Hepatol. Jul. 2010;25(7):1299-1305. [pmid: 20594260].
82 Eltawil KM, Berry R, Abdolell M, Molinari M. Quality of life and survival analysis of patients undergoing transarterial chemoembolization for primary hepatic malignancies: a prospective cohort study. HPB (Oxford). May. 2012;14(5):341-350. [pmid: 22487072].