# DISCUSSION

We systematically reviewed and critically appraised trials and observational studies examining the risks and benefits of HCC screening in patients with chronic liver disease. Periodic ultrasound and/or alpha-fetoprotein testing have been the most commonly evaluated screening modalities. Patients with viral hepatitis have been the most frequently studied populations. Although screening identifies patients with early-stage HCC and some patients with early-stage HCC selected for curative therapy do well, there is very low strength evidence from which to draw conclusions about the balance of benefits and harms of screening for HCC and treating HCC found as a result of screening across a population of patients.

The body of evidence was limited in part by the paucity and substantial methodologic shortcomings of screening trials. Indeed, the one large-scale trial conducted among hepatitis B infected patients in China that serves as the primary evidence base for these recommendations has serious methodologic limitations which undermine the validity of its findings.28 The other trial found serial AFP screening offered no survival advantage.29 Limited applicability, because of more widespread imaging use, higher rates of incidental diagnosis, and a smaller proportion of patients whose main risk is hepatitis B, further diminish the strength of evidence.

Though we found a large body of observational studies, they did not substantively add to the strength of evidence. Most were single center studies retrospectively evaluating patients with HCC and had several methodologic flaws, in addition to lead- and length-time biases. Four studies attempted to account for lead-time bias and 3 of them found, in doing so, that the survival advantage of screening was greatly attenuated. However, estimates of lead-time bias are uncertain at best in part because there are few data available about the natural history of early-stage or screen-detected HCC from which to estimate tumor doubling times. The small amount of information that does exist comes from older studies that suggest tumor growth patterns can differ markedly among patients, with some patients exhibiting steady growth, others no growth followed by a period of rapid growth, and others still with little to no long-term growth.67-70 Another study of a mixed population of patients with early- and late-stage disease randomized to no treatment in 2 trials found 2 very different survival patterns depending on the presence or absence of an invasive tumor pattern and poor performance status (8 vs 50% 3-year survival, p=0.00010).71

Potentially curative treatments for HCC such as liver transplant and resection exist, but have the potential for substantial perioperative morbidity and mortality. Trials comparing screening intervals show that most of the HCC identified as a result of periodic screening were small, early-stage HCC.30,31 If many of the HCC found as a result of routine screening would progress and cause morbidity before patients' underlying illness did, then the net balance of benefits and harms might favor widespread screening. If, on the other hand, HCC identified as a result of screening were more indolent, then the risks of treating disease that would not have otherwise been clinically relevant (ie, overdiagnosed HCC) might tip the balance away from routine screening. Unfortunately, we found no evidence examining rates of overdiagnosis. Many HCC are diagnosed with imaging alone, in part because of concerns over the risks of liver biopsy. The accuracy of such diagnoses – and the corresponding risk of overtreatment – may also be important considerations in evaluating the balance of benefits and harms of screening. A forthcoming systematic review examining the diagnostic accuracy of imaging tests for HCC should help address this knowledge gap.72

Most patients with HCC diagnosed with screening had smaller tumors that would be potentially amenable to curative therapies such as resection or liver transplantation. Cohort studies suggest that long-term survival of patients undergoing liver resection or transplantation for HCC is quite high, but such treatments may be associated with substantial perioperative morbidity and mortality.27,73 Whether there is a net benefit from aggressive treatment of all early stage HCC is unclear from current data. We found little trial data focused on early-stage HCC treatment, and reporting of harms was inconsistent. The reasons why patients were not selected for surgical therapy are not clear. If there were random variations in patient selection practices, then the observational studies showing that surgically treated patients had markedly increased survival compared to nonsurgically treated patients would be quite compelling. If, on the other hand, patient factors such as comorbidity burden, performance status, and social determinants of health were the main considerations in influencing the decision to undergo treatment then the potential for confounding may be considerable. A recent US study found that tumor stage and performance status were the factors associated with receipt of curative therapy.74 There is also emerging evidence that the waiting period for OLT selects patients with more indolent HCC, since patients with more aggressive disease lose candidacy while awaiting transplant.75

We found few other systematic reviews examining HCC screening studies. A recent Cochrane review similarly found insufficient evidence for screening, but focused only on studies of HBV patients and did not examine observational studies.14 Several widely disseminated guidelines recommend HCC screening in high-risk patients with liver disease,8-10 but none used a systematic review which critically appraised included studies as a basis for the recommendations. Other systematic reviews have evaluated HCC treatment trials but, apart from the TACE trials discussed above, they included trials of patients with late-stage HCC.76,77

Our finding that the strength of published evidence examining HCC screening is very low neither supports nor refutes current clinical policy recommendations for HCC screening. Transparency about the strength of evidence on which these recommendations are based is important, but policy recommendations also take into account other factors such as patient values and preferences, expert opinion, and cost considerations.78 It is likely to be the case that there is variation in the natural history of screen-detected HCC. Additional information clarifying natural history patterns and ways of distinguishing patients with more aggressive tumors from those with more indolent tumors might facilitate patient selection practices that would optimize the benefits of screening while minimizing the risks of overdiagnosis.

## LIMITATIONS

One limitation of our review was the exclusion of articles whose full-text was not in English. However, we mitigated the risk of missing relevant studies by searching multiple databases, bibliographies, speaking with experts, and searching trial registries. Moreover, there is evidence to suggest that language restrictions do not bias results of reviews of conventional therapies.79 Our focus on studies comparing active treatment to conservative management admittedly may have missed important effects of current treatments for HCC, since many have been evaluated in the context of comparative effectiveness studies. However, a comparative effectiveness review of current treatments for HCC was beyond the scope of our review and would not have provided direct evidence about the utility of treating screen-detected HCC. Also, we did include systematic reviews of current treatments as a way to broaden our understanding of the benefits and harms of current therapies. We excluded studies of patients with advanced stage HCC so our findings apply only to patients with early stage disease. While it is possible that screening would identify some patients with advanced stage disease, the incremental effects of routine screening compared to clinical or incidental diagnosis would mainly be to increase the number of early stage HCC detected.

## FUTURE STUDIES

Overall, we found little high-quality direct evidence from which to draw conclusions about the balance of benefits and harms of routine HCC screening. There are a number of opportunities for further study and it is likely, given the current insufficient body of evidence, that future studies will have a substantial impact on the strength of evidence. The key evidence gaps and suggestions for corresponding future research opportunities are summarized in Table 1.

Table 1 Gaps in evidence and recommendations for future research

Topic | Evidence gap | Potential future research
Screening
| No methodologically sound trials have examined the effects of screening on health outcomes in patients with chronic liver disease. | Trials examining the health outcome effects of screening should be considered, including patients with hepatitis B, hepatitis C, and other forms of chronic liver disease.
| The feasibility of conducting randomized trials of screening in patients with chronic liver disease has been questioned. | Future studies should evaluate public willingness to participate in screening studies based on available evidence in the US and including patients with hepatitis C.
| Observational studies are limited by selection bias, limited generalizability (mostly single-center), retrospective design, and inability to identify time at risk for HCC. | Large registries of patients with chronic liver disease, with prospective recording of date of diagnosis of chronic liver disease, date of cirrhosis diagnosis, screening practice, imaging findings, HCC diagnosis, and treatment received.
| The contemporary natural history of early-stage HCC detected by imaging tests is not well understood. | Prospective cohort studies examining the growth patterns of small (< 2 cm) liver lesions suspicious for HCC should be considered. Studies would ideally examine and compare independent interpretations of serial imaging studies.
| The harms of screening have not been well-explored. | Studies examining the psychologic effects of screening (anxiety, depression) should be considered. Registry studies should include information about the cost of initial screening as well as the rates of repeat imaging required for initial positive results and associated resource use and harms.
| Current guidelines recommend 6 month screening intervals. Two trials demonstrate that 3- or 4-month screening intervals are not associated with benefit compared to 12-month intervals. However, no trials have compared 6 to 12 month screening intervals. | Trials comparing 6 to 12 month screening intervals should be considered.
Treatment
Overall | The benefits and harms of treating very early stage HCC compared to a watchful waiting strategy are unknown. | Trials comparing various treatment strategies to watchful waiting for very early stage HCC should be considered.
TACE | Trials of TACE have included mixed populations with early and late stage disease. Trials have been small and have not included patients with hepatitis C. | Trials examining the effects of TACE on health outcomes in patients with early-stage HCC should be considered. Trials should include patients with hepatitis C.
RFA | No trials have examined the health outcome effects of RFA. Observational studies are limited by biases such as confounding by indication. | Trials comparing RFA to conservative treatment in patients with early stage disease may be considered. In the absence of such trials, prospective cohort studies using well-designed registries of patients with chronic liver disease should be conducted, using techniques such as propensity scoring to control for confounding factors related to patient selection. Rates of needle-track seeding and other complications should be examined in these prospective studies.
OLT | No trials have examined the benefits and harms of OLT for patients with HCC compared to conservative treatment. Harms associated with OLT for HCC have not been well reported in observational studies. | Prospective cohort studies using well-designed registries of patients with chronic liver disease should be conducted, using techniques such as propensity scoring to control for confounding factors related to patient selection. Rates of perioperative morbidity and mortality, as well as longer-term harms such as infectious complications should be examined in prospective studies.
Resection | No trials have examined the benefits and harms of resection for patients with HCC compared to conservative treatment. One observational study did attempt to control for patient selection factors and found resection was associated with lower mortality, but did not explicitly account for some important confounding factors such as patient comorbidity and performance status. While perioperative mortality had been well-examined, most of the data are over a decade old and applicability to current practice is unclear. | Prospective cohort studies using well-designed registries of patients with chronic liver disease should be conducted, using techniques such as propensity scoring to control for confounding factors related to patient selection. Rates of perioperative morbidity and mortality, as well as longer-term harms should be examined in contemporary prospective studies.
Sorafenib | No trials have examined the benefits and harms of sorafenib in patients with early stage HCC. | Trials and prospective cohort studies of sorafenib in patients with early-stage HCC should be considered.

The current body of published evidence does not, in and of itself, appear to constitute a threat to clinical equipoise over the health outcome effects of HCC screening. Experts have, however, raised other concerns about the ethics and feasibility of conducting such a study. The research and health care community should continue discussions about the feasibility and equipoise of an HCC screening trial.

Research to more definitively evaluate the balance of benefits and harms of treating early stage HCC is imperative. Even in the absence of randomized controlled trials of screening, observational studies using well-designed registries of HCC patients, their treatments, complication rates, and long-term outcomes could prove useful. These registries should include consecutive patients and prospectively collect clinical information about potential adverse effects over time. Studies examining the psychologic impact of screening are also needed.

Imaging tests can clearly identify small, early-stage HCCs. Future studies should evaluate the contemporary natural history of such lesions and consideration should be given to treatment trials that include a watchful waiting arm for very early HCC.