# PEER REVIEW COMMENTS AND RESPONSES

| Reviewer | Comment | Response
| Question 1: Are the objectives, scope, and methods for this review clearly described?
1. | 1 | Yes. Very impressive.
2. | 2 | Yes. The methods section pertaining to inclusion of systematic reviews of comparative effectiveness studies is a little unclear—at first it says these studies were excluded, but then it says you included reviews of comparative effectiveness studies (if I'm understanding correctly). I didn't really see anything in the results comparing one active treatment to another so it seems to me that it would be clearer to just say that studies that compared active treatments were excluded—unless there was some specific outcome or reason that you included them, and then just say “we included systematic reviews of studies that compared active treatments and reported xx outcomes” or something like that—which I think would be more straightforward. | We agree. We initially had looked at these studies to gather more information about treatment-specific harms, but we agree that the majority of harms data we report are from cohort studies. We've clarified that studies that compared active treatments were excluded.
3. | 3 | Yes (no comment)
4. | 4 | Yes (no comment)
5. | 5 | Yes. Effects of HCC surveillance on mortality in pts with chronic liver disease
6. | 6 | Yes (no comment)
7. | 8 | Yes. Although the objectives, scope, and methods for this review are clearly described, they do not specifically address issues related to the situation in the Veterans Health Administration. In an e-mail dated 19 February 2013 to the ESP, I had indicated that this was an issue of major interest to my office. | The scope of the review was broad enough to have captured studies both directly and indirectly relevant to VA. We did include a section (in Results) specifically focused on VA studies. In our edits, we added more detail to our discussion of the 3 VA observational studies and more about current screening practices in VA. We agree that the background should have included VA-specific information - we've added some information about change in prevalence of HCV and HCC diagnoses in VA over time.
8. | 9 | Yes
| 2. Is there any indication of bias in our synthesis of the evidence?
9. | 1 | No (no comment)
10. | 2 | No (no comment)
11. | 3 | No (no comment)
12. | 4 | No (no comment)
13. | 5 | No. Just the exclusion of articles not in English
14. | 6 | No (no comment)
15. | 8 | Yes. The failure to consider the natural history of HCC introduces a serious methodologic flaw that biases the results towards the finding that there is not evidence to support treatment of early HCC . The implicit assumption that HCC is similar in its biologic behavior to malignancies such as prostate cancer – where patients may survive for decades without treatment – is incorrect (please see comments 3 and 4 infra). If applied to non-small cell lung cancer, the approach used here would likely conclude that there is insufficient evidence to support resection of stage 0 or stage 1A NSCLC. | We agree that the natural history of HCC is important contextual information. In the initial draft, we did consider natural history in the discussion, albeit briefly. In our edits, we have expanded our discussion of natural history and the implications of natural history on the overall balance of risk/benefit for HCC screening. Much of the information about the natural history of early-stage HCC is several decades old. What information there is suggests that the natural history of early-stage HCC varies.
16. | 8 | In addition, the failure to include trials that compare 2 different modalities systematically excluded evidence that supports treatment of early HCC. | Throughout the report, we have clarified that we evaluated treatment studies only as a way to indirectly evaluate the effects of screening. Because this review was focused on screening, we looked for evidence of the effects of treating screen-detected (or early-stage HCC) compared to no treatment. Studies comparing 2 or more active treatments would not have provided evidence about the effects of treating screen-detected disease.
17. | 8 | In addition, the discussion of harms from evaluation of liver lesions detected via surveillance failed to note that the diagnosis of HCC is most often made by imaging rather than biopsy. This consideration was communicated in my e-mail of 19 February 2013, but not addressed in this document. | The initial draft's discussion section did include a statement about diagnoses most often occurring as a result of imaging rather than biopsy. Nevertheless, we have re-written the screening harms section to clarify that, in considering harms, we considered the harms of the initial screening tests themselves as well as the harms of additional testing done in response to initial positive screening test results. We agree that liver biopsy is not commonly performed for the diagnosis of HCC, but it is performed sometimes and the harms are important to consider. In our re-drafted section, we clarify that few studies reported testing actually performed. The 2 studies that reported rates of liver biopsy used in HCC diagnosis reported 33 and 80% of patients had liver biopsy performed. We also clarified in the summary of evidence table that there was limited directness of information about harms (since most had to do with needle track seeding and biopsy is not often used in current practice).
18. | 9 | Yes. The search methodology is well explained and most of the relevant direct evidence has been captured. There are however several problematic issues. Based on the review, there is a large body of observational studies that consistently show an association between HCC surveillance and HCC diagnosis at an early stage, increase receipt of resection or transplant, and increased survival. This is understandably not grade 1 evidence but it is grade 2. Expressing the data as “there is no evidence” is inaccurate. Rather, there is evidence of grade 2 level that consistently indicate xxx etc. | We disagree that we characterized the data as “there is no evidence”. We graded the evidence as “insufficient” because it is impossible to know whether the improved survival observed in these studies among screen-detected patients was related to a true effect of screening or, rather, to lead-, length-, and selection biases common to the studies. There are also important inconsistencies among studies – 3 of 4 studies that attempted to correct for lead-time found survival advantages attenuated with longer tumor doubling time assumptions. Nevertheless, we agree that readers could misinterpret the term “insufficient” as “there is no evidence”. Therefore, we elected to use GRADE terminology to summarize the strength of evidence rather than the AHRQ terminology we originally used. Using GRADE, we believe the strength of evidence would be “very low”. We have used this term in place of insufficient in our edited draft and hope this will better communicate that there are indeed studies, but that any conclusions drawn from this body of evidence are very tenuous.
19. | 9 | There seems be “kitchen sink” approach of piling disadvantages of the two RCT, but not enough follow through as to the possible consequences of the disadvantages. A couple of limitation like low screening rates, and inclusion of non cirrhotics would bias the results toward the null (not the opposite). | We agree that this section could have been more thoughtfully presented. We've rewritten to include a more precise discussion of how various deficiencies might affect the results.
20. | 9 | For TACE, they seem to ignore the meta analyses of RCT (and observational studies) which demonstrate statistically significant benefit in survival. For sorafenib, there is no mention! It is the only RCT proven efficacious intervention for palliative therapy of HCC. | These studies were not included because we were focused on screening efficacy and, therefore, focused only on studies evaluating the effects of treating early-stage HCC (since the effects and rationale for screening is most likely to increase the detection of earlier stage disease). The TACE meta-analysis included the 3 trials we included plus a fourth (the Llovet Lancet trial) that we excluded because it included only patients with advanced stage disease. Likewise, sorafenib has only been evaluated inpatients with advanced stage disease. We have clarified throughout the report that we were focused on this specific subgroup of treatment studies. We agree that, though this language was in the initial draft, readers might have missed that we were not evaluating HCC treatment in general. We also include an additional statement in the limitations section that this review applies only to early-stage disease and not advanced stage, and we acknowledge that some patients undergoing screening could have newly discovered advanced stage disease.
21. | 9 | The search did not get into the many studies that report survival of patients who were listed but not transplanted compared to those listed and transplanted (at the same stage). | We included comparative and non-comparative observational studies of OLT if they included patients with early-stage disease.
22. | 9 | In the summary, there is no numerical emphasis on worst case scenario against HCC surveillance (for example mentioning the point estimate of the meta analysis for tumor seeding but not the 95% CI or the more recent study described in the body of the document). Long term survival (which is quiet good) with resection and transplant is presented without numbers. | We have included the long-term survival numbers, the CI information, and we also note in the table the most recent needle-track seeding study.
23. | 9 | Certainly the summary of the document is not accurate or supported by the data: consistent evidence of grade 2 is not the same as insufficient evidence to draw conclusions. | See response to comment #18.
24. | 9 | Feasibility and ethics of RCT need also to be addressed in light of existing studies that indicate that patients are unlikely to accept such a trial when (nothing is one of the arms). | We have included this as an important area for future research.
25. | 9 | Some references; 1. Poustchi H, Farrell GC, Strasser SI, Lee AU, McCaughan GW, George J. Feasibility of conducting a randomized control trial for liver cancer screening: is a randomized controlled trial for liver cancer screening feasible or still needed?. Hepatology. Dec. 2011;54(6):1998-2004. [doi: 10.1002/hep.24581]. [pmid: 21800340]. .; 2. Llovet JM, Bustamante J, Castells A, Vilana R, Ayuso Mdel C, Sala M, Brú C, Rodés J, Bruix J. Natural history of untreated nonsurgical hepatocellular carcinoma: rationale for the design and evaluation of therapeutic trials. Hepatology. Jan. 1999;29(1):62-7. [pmid: 9862851]. .; 3. Davila JA, Duan Z, McGlynn KA, El-Serag HB. Utilization and outcomes of palliative therapy for hepatocellular carcinoma: a population-based study in the United States. J Clin Gastroenterol. Jan. 2012;46(7):71-7. [doi: 10.1097/MCG.0b013e318224d669]. [pmid: 22157221]. .; 4. Altekruse SF, McGlynn KA, Reichman ME. Hepatocellular carcinoma incidence, mortality, and survival trends in the United States from 1975 to 2005. J Clin Oncol. Mar. 20. 2009;27(9):1485-91. [doi: 10.1200/JCO.2008.20.7753]. Epub 2009 Feb 17. [pmid: 19224838]. .; 5. Schwarz RE, Smith DD. Trends in local therapy for hepatocellular carcinoma and survival outcomes in the US population. Am J Surg. Jun. 2008;195(6):829-36. [doi: 10.1016/j.amjsurg.2007.10.010]. Epub 2008 Apr 23. Review. [pmid: 18436176]. .; 6. El-Serag HB, Siegel AB, Davila JA, Shaib YH, Cayton-Woody M, McBride R, McGlynn KA. Treatment and outcomes of treating of hepatocellular carcinoma among Medicare recipients in the United States: a population-based study. J Hepatol. Jan. 2006;44(1):158-66. Epub 2005 Nov 2. [pmid: 16290309]. .; 7. El-Serag HB, Mason AC, Key C. Trends in survival of patients with hepatocellular carcinoma between 1977 and 1996 in the United States. Hepatology. Jan. 2001;33(1):62-5. [pmid: 11124821]. .; 8. Davila JA, El-Serag HB. Racial differences in survival of hepatocellular carcinoma in the United States: a population-based study. Clin Gastroenterol Hepatol. Jan. 2006;4(1):104-10. quiz 4-5. [pmid: 16431312]. .; 9. Leung JY, Zhu AX, Gordon FD, Pratt DS, Mithoefer A, Garrigan K, Terella A, Hertl M, Cosimi AB, Chung RT. Liver transplantation outcomes for early-stage hepatocellular carcinoma: results of a multicenter study. Liver Transpl. Nov. 2004;10(11):1343-54. [pmid: 15497158]. . | Most of these provide background or contextual information. We have reviewed all these studies and included them in background or discussion as appropriate. We have re-written the background to include more information on changing HCC incidence (including the Altekreuse reference). We did examine the Leung study for inclusion as a comparative observational study. However, it compared HCC patients receiving OLT to patients receiving OLT for non-malignant disease. Because there were several large national OLT cohorts, we only examined noncomparative OLT studies with > 500 patients. The 5-year survival reported in this smaller cohort was quite similar to the survival we report from the larger cohorts.
| 3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
26. | 1 | No (no comment)
27. | 2 | No. Not that I'm aware of.
28. | 3 | No. Not that I know of.
29. | 4 | No (no comment)
30. | 5 | No. None that I am aware of
31. | 6 | No
32. | 8 | Yes. Note: These are only a small portion of the literature that could be cited that contradicts the findings in this document, particularly with regard to treatment of early HCC.; 1. Cho YK, Kim JK, Kim MY, Rhim H, Han JK. Systematic review of randomized trials for hepatocellular carcinoma treated with percutaneous ablation therapies. Hepatology. Feb. 2009;49(2):453-9. [pmid: 19065676]. .; 2. El-Serag HB, Siegel AB, Davila JA, Shaib YH, Cayton-Woody M, McBride R, McGlynn KA. Treatment and outcomes of treating of hepatocellular carcinoma among Medicare recipients in the United States: a population-based study. J Hepatol. Jan. 2006;44(1):158-66. [pmid: 16290309]. .; 3. Llovet JM, Real MI, Montaña X, Planas R, Coll S, Aponte J, Ayuso C, Sala M, Muchart J, Solà R, Rodés J, Bruix J, Barcelona Liver Cancer Group. Arterial embolisation or chemoembolisation versus symptomatic treatment in patients with unresectable hepatocellular carcinoma: a randomised controlled trial. Lancet. May. 18. 2002;359(9319):1734-9. [pmid: 12049862]. .; 4. McMahon BJ, Bulkow L, Harpster A, Snowball M, Lanier A, Sacco F, Dunaway E, Williams J. Screening for hepatocellular carcinoma in Alaska natives infected with chronic hepatitis B: a 16-year population-based study. Hepatology. Oct. 2000;32(4 Pt 1):842-6. [pmid: 11003632]. .; 5. Orlando A, Leandro G, Olivo M, Andriulli A, Cottone M. Radiofrequency thermal ablation vs. percutaneous ethanol injection for small hepatocellular carcinoma in cirrhosis: meta-analysis of randomized controlled trials. Am J Gastroenterol. Feb. 2009;104(2):514-24. [pmid: 19174803]. .; 6. Schwarz RE, Smith DD. Trends in local therapy for hepatocellular carcinoma and survival outcomes in the US population. Am J Surg. Jun. 2008;195(6):829-36. [pmid: 18436176]. . | We had reviewed most of these studies. They were excluded for following reasons: Cho – comparative effectiveness studies El-Serag – no outcomes specific to patients with early-stage disease. Llovet – trial included only patients with advanced stage disease. McMahon – we excluded observational screening studies with historic controls (because there were plenty of studies with contemporary controls and the use of historic controls would have introduced one more source of bias). Orlanda – comparative effectiveness Schwarz – no outcomes information specific to patients with early-stage disease.
33. | 9 | Yes. Population based US data on survival of patients with HCC who were transplanted. There are several publications based on UNOS data that show excellent (70% plus 5 year recurrence free survival) survival among HCC patients who received liver transplants. | We included several large OLT cohorts including a large UNOS cohort. We agree long-term survival was good and we reported this.
34. | 9 | There are multiple publications from population based US based cohorts (plus the publicly available SEER data) that show stage specific survival of patients with HCC, and again clearly showing remarkable improvement with transplant and resection compared to patients with similar stages who did not get transplanted/resected. These are observational studies but the magnitude of differences is dramatic. | In initial draft, we did not include the comparative numbers in the summary of evidence (only in the text) – we've now added this to the table. We reported that survival in patients selected for surgery is quite good and markedly better than patients not selected for surgery. We have added more to the discussion about the potential explanations for such findings – unclear whether this is a true treatment effect or whether this difference reflects careful patient selection and confounding by indication.
35. | 9 | There are also publications of US based population based cohorts that show unfirmly grim prognosis of untreated patients with HCC (irrespective of stage if one looks at 5 year survival). Compare with 5 year survival of transplant/resection. | See above
36. | 9 | The harms is remarkably deficient and biased. There is mention of harms of biopsies for liver cancer, and harms of different treatments, but nothing about ultrasound of the liver or blood draws (for AFP). This is akin to talking about the harms of colorectal resection or chemotherapy but not colonoscopy or FIT (for CRC screening) or harms of breast biopsy (but not mammography). Both ultrasound and blood draws (which is the method used to obtain AFP) for all kinds of indications have been around for decades and there is considerable safety data on both. | We have re-written the screening harms section to clarify that, in considering harms, we considered the harms of the initial screening tests themselves as well as the harms of additional testing done in response to initial positive screening test results. We acknowledge that ultrasound and blood draws are, themselves, likely quite safe. Nevertheless, it is still important to consider the harms of testing done in response to initial positive screening test.
37. | 9 | There is a lot of discussion on TACE (which is appropriate) but there is a remarkable avoidance of the one palliative therapy that has grade 1 evidence of efficacy from multiple very well done modern RCTs, namely sorafenib. This agent can only be applied (and has only been tested in those with compensated cirrhosis (mostly Child A) and mostly asymptomatic/mildly symptomatic patients. Surveillance even if it does not detect early cancer that is treated with potentially curative therapy, will detect asymptomatic cancer which could be treated with efficacious palliative treatment. The days of removing patients who are not candidates for liver transplant from surveillance consideration are gone. | See response to #20. While it is true that some patients undergoing screening will have asymptomatic advanced stage disease identified, the intent and results of screening are to increase the detection of early-stage disease. Trials evaluating screening intervals found, in both groups, that screening mostly increased the number of early-stage small tumors. While we acknowledge that our review does not cover the detection and treatment of advanced stage disease, we believe a focus on early-stage disease is appropriate for the discussion of screening.
38. | 9 | There are actually four RCT of TACE/TAE (check recent meta analyses) | See above #20.
| 4. Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
39. | 1 | It is only the cost of CT and MR that precluded their inclusion in the AASLD PG. I was on that committee when the issue came up. Everyone I know uses AFP to screen despite the nonsensical “firing of the AFP” by that PG. I have seen MANY advanced HCCs that were missed on u/s and obvious on CT. CT as performed in the US for HCC screening is dreadfully insensitive. | Noted. We searched for any screening studies using any of these potential screening modalities. Most studies included patients who were detected with U/S and/or AFP.
40. | 2 | a. In a number of places the report refers to radiofrequency ablation but doesn't mention TACE as another “active” treatment. These are not the same thing so both should be mentioned. | We cover both RFA and TACE.
41. | 2 | b In the section describing the RCT's of screening vs. no screening there is some discussion of the Chinese staging system which might warrant some revision. The report states that the Chinese system doesn't consider liver disease severity which is not quite true, as jaundice/ascites/cachexia etc are markers of disease severity (and to my understanding such clinical markers are now included in the Barcelona and other staging systems). I think the more accurate critique would be to note that the Chinese studies used a different staging system than currently used in the U.S. and Europe that didn't include factors such as tumor size, number of lesions, and location of lesions, and focused on clinical markers of disease severity (if I'm stating this accurately) and leave it at that. | We have re-written the trial results section to be more precise about the effects of each flaw, including the staging system.
42. | 2 | c In the section on screening vs. no screening it would be helpful to at least report some summary of the difference in survival reported in the observational studies. I would focus on adjusted estimates only and report the median difference with the range. Right now there is really no quantitative report of the results so it's hard for readers to know what to make of it. Even if the data are unreliable providing some numbers can give readers some sense of the potential magnitude of effect, whether confounding is likely to explain much or all of the results, inconsistency, etc. | We have re-drafted the screening observational studies table to make it easier to find the survival and HR data. We have also created a new figure displaying comparative survival information. Finally, we have included a summary of this information in the relevant parts of the results section.
43. | 2 | d Same for the section on active treatments vs. conservative treatments—for the RCT's I'd suggest reporting the actual results from the two studies that didn't report any significant effect on survival and for the observational studies reporting some information regarding the differences between treatment and no treatment. | This information is included in the treatment studies table.
44. | 3 | No comments – well done review.
45. | 4 | The review addresses internal validity (risk of bias) of the trials quite well. I wonder if a statement about external validity (applicability/generalizability) might not also be useful. The reason is that many Hep C providers use the Chinese trial of patients with hep B as the basis for recommending screening/surveillance for HCC in hep C patients. Clearly that trial is not sufficient for recommending screening, even for hep B patients, but there may be an additional issue with extrapolating the results (however interpreted) to hep C patients. | We included such a statement in our revisions.
46. | 5 | Under data extraction, in addition to mode and frequency of surveillance it would be interested to review technical limitations of surveillance. A main limitation of ultrasound surveillance is the poor visualization of the liver parenchyma in patients with more advanced cirrhosis and fatty change. In these patient populations, the detection of early HCC, and particularly smaller HCC lesions, is limited. These limitation would likely have an impact on surveillance efficacy. | This was beyond the scope of our review. However, an AHRQ review is currently being completed that covers just this topic.
47. | 6 | a. Overall, a great job going through a large number of studies. The draft report is clearly written and well structured to present results at different levels of detail, depending on the reader's specific needs.
48. | 6 | b In oncology, surveillance means looking for recurrence of a prior cancer; thus, the title and report should not use that term but rather screening for HCC. Screening = looking for cancer in those without a prior diagnosis of cancer. This is more than semantics as the continued misuse of the term surveillance tends to separate HCC screening from a wealth of knowledge about cancer screening which seems to be ignored in this context. This sentence seems to highlight the problem: “However, recommendations for HCC surveillance remain controversial in part because of concerns over the quality and paucity of existing evidence, and because there have been concerns raised about overdiagnosis and patient harms in other cancer screening programs”. It is too easy for some to ignore this sentence because HCC surveillance is not a cancer screening program. At the very least you should include a definiton of terms and clear statement that HCC “surveillance” is in fact a type of cancer screening and not cancer surveillance as would be done after surgical resection of HCC. | We agree – we have changed the terminology to screening from surveillance.
49. | 6 | c In the executive summary, it would be helpful to separate the review of the two RTCs from the non-RTCs. In particular, the latter RTC seems to have flaws that were not considered by the guideline writing groups and may not be well known to the end users of this ESP report who read only the Executive Summary. | We have done so.
50. | 6 | d Please consider including overdiagnosis bias as another confounder for non RTCs of HCC screening, and perhaps comment on the magnitude of overdiagnosis in the two RTCs. | We have included more in the discussion about natural history and about uncertainty regarding the potential for overdiagnosis in screen-detected HCC. We could not estimate the magnitude of overdiagnosis in the RCTs, but we do make note of the trials comparing screening intervals in which more early-stage patients were found and treated in the intensive screening group without an improvement in survival.
51. | 7 | While I think the paper probably reaches the right conclusion, the whole paper seems to be somewhat disjointed and a bit frustrating to read. A reader gets the sense of “diffuse anxiety” about how studies were not well-done. While that may be generally true, I wonder if the authors could be more constructive to the field with some more detailed critique and assessment and suggestion. For example:; a. What is the ‘best evidence’ and how good is it?; On p9, you don't really explain what you are looking for, regarding “quality of evidence” or “magnitude of effect.” Later you will describe weaknesses of many studies, but the weaknesses are described for several studies at a time rather than individual studies, and a reader was left wondering “is there a baby somewhere in this bathwater; is there ANY study that qualifies at ‘best’ and is that ‘good enough’”. My hunch is that the answer is no; for example both the Chinese RCTs have major deficiencies. But if that's the case then maybe be clear about it. | We agree. As reported above, we revised the results section to be clearer about the flaws and their implications. We also reconfigured the observational studies results section and discuss the 3 “best” studies earlier.
52. | 7. | b Summaries; On p13, right above observational studies, you've just finished a 2-page review of RCTs. But you write no summary of what you think of the 2 pages you have written. There is no indication that you've synthesized or evaluated this entire group of studies. (This is not clearly done in the Discussion either). You simply end with critique of whatever trial happened to be last. In contrast, a reader would like to know “What is your bottom line about this whole class of studies, about what you have just told me? Do any come close to being satisfactory to draw a conclusion? Is the quality of all unsatisfactory? Can we take away any idea about magnitude of any impact, or is quality so bad (or magnitude so low) that we can't? | We agree. We have included a summary paragraph at the beginning of both the screening and treatment sections.
53. | 7. | Most of the following sections have the same problem: You write paragraphs about individual studies or groups of studies, but you don't summarize at the end of each section what you have described and what you think it means. For example look at the last full paragraph on p14; there's no summary, just diffuse anxiety (again probably warranted); but the whole process looks like you are just throwing up your hands. Ditto for sections on lead-time bias, harms, treatment. | See above.
54. | 7. | c Other organization; On p13, in observational studies, you need to remind the reader “what question were you looking at” - benefit, harm, other? | We have revised the section headings accordingly
55. | 7. | d Current guidelines; The current guidelines section has the potential to be interesting, to the extent that other guidelines recommend FOR surveillance. When they do, can you:; 1. describe what is their recommendation (it's in the Table);; 2. what it that based on (what evidence; what studies, what statements about benefit vs risk). Some of this may be buried in Table 12, but can you distill the essence and explain what you think the problem is?; 3. how you judge (2).; Right now you seem to rely on saying the guidelines aren't any good because (p19, first para) you “identified several methodological flaws…”. Can you elaborate more on the details in Appendix D, Table 12: How strong or weak is an overall quality grade of 2 or 3? How serious are the generally low grades in rigor of development? Enough to be disqualifying? Can you say any detail about what specific studies about the evidence each guideline seems to rely on - which study, what magnitude of benefit and of harm? Do they rely on the Chinese RCTs, now largely-discredited? Or other? Right now the whole thing seems somewhat an abstract exercise; can you give it a little more detail and life, in interpreting/summarizing the data in the Tables and in your text summary? | We have revised this section accordingly.
56. | 7. | e Future studies; On p22, 2nd para in Future Studies, you could provide much more help to the field by being more specific about what you think should be done in the future, based on what you have learned from your reviews. The recommendations for “consecutive patients” and “prospectively collected …. about adverse effects” seems somewhat generic. In earlier text you've discussed lead-time bias, trying to adjust for it, and other sources of problems. Can you, then, in this section, try to tell future-researchers how to improve what they are doing. | We agree. We now included a future studies table that pairs study suggestions with the evidence gap they are meant to address.
57. | 8 | Background; 1. Page 1 - The statement that the 5 year survival for HCC is 16.5% is incorrect. The cited statistics from references 1-2 refer to the SEER category of “liver and intraductal bile duct cancers,” [underlined: not] HCC. In addition, reference 1 specifically notes incomplete reporting of VA cancer registry data to state cancer registries, a factor that makes relevance of the cited data to VA unclear.; A population-based study of 2,963 HCC patients based on the linked SEER-Medicare dataset found a median survival of 104 days with a 3 year survival rate of 5.7%, not the 16.5% rate cited in this review (El-Serag et al. 2006). | There are issues with all long-term survival estimates we found. The SEER data is the most current though we agree it is flawed in that there are some non-HCC cases included. However, HCC are likely to be the majority. We added an additional reference and present the mortality as a range. We believe this shows there is a range, while underscoring the original point which was that long-term survival is poor. The SEER-Medicare data includes mostly (91%) patients > 65 so it is not surprising the long-term survival reported here was lower.
58. | 8 | 2 Page 1 - The statement that “the National Cancer Institute recommends against surveillance” is incorrect. The source relied on for this statement, reference 8, explicitly states that “The summary reflects an independent review of the literature and does not represent a policy statement of NCI or the National Institutes of Health (NIH). | We have taken this out.
59. | 8 | Page 1 - The statement that “recommendations for HCC surveillance remain controversial” is based solely on reference 12, an opinion piece (not an original study) written by two VA authors who failed to disclose that they were attempting to secure VA funding to support a placebo-controlled study of surveillance. | We have consolidated the background section and added additional references.
60. | 8 | Methods; 1. Page 8 - No statistical justification is provided for the arbitrary sample size of 500 patients required for inclusion of studies involving OLT. | We did not use a sample size limit for observational studies comparing treatment to no treatment. The sample size of 500 patients applied to noncomparative observational studies – as such, there is no statistical testing. Rather, we included such studies both as a way to understand harms of treatment as well as long-term survival. The sample size of 500 was chosen because there were several, large noncomparative observational studies of OLT and we felt these would provide more generalizable data regarding long-term survival and harms. The smaller, noncomparative observational studies we examined had similar findings and would not have changed the results – good long-term survival and poor reporting of harms.
61. | 8 | 2 Page 8 – The rationale for not including studies that compared two or more active treatments was not provided. Active-controlled studies are well recognized as a valid mechanism for establishing efficacy of an intervention, particularly when ethical considerations preclude a placebo or no-treatment arm. Of note, the PCORI methodology relied on by the review (reference 23) explicitly endorses active comparator studies; PCORI standard RQ-5 states that “non-use (or no specific treatment) comparator groups should be avoided unless no specific treatment is a likely option in standard care.” | The PCORI causal inference standards to which we refer apply to observational studies. The active-controlled studies guidance applies to situations in which the benefits of treatment have been established. The strength of evidence for HCC screening depends in part on the balance of benefits and harms of treating screen-detected disease. Screening is likely to detect additional small, early-stage HCC. The efficacy of treating such screen-detected tumors compared to watchful waiting is the question that applies most directly to the HCC screening and we were tasked – after discussion with a group of topic-specific and screening-methodology experts - with finding and examining such studies. Examining active comparator studies would not have contributed substantially to the strength of evidence for HCC screening. We have clarified that our approach to the treatment literature was meant to examine the relative benefits of treating screen-detected disease and that our review does not examine the issue of HCC treatment as a whole.
62. | 8 | 3 Page 9 – The statement that there is no widely accepted standard for quality assessment of observational studies” is incorrect. The Strobe (Strengthening the Reporting of Observational Studies in Epidemiology; www.strobe-statement.org) is referenced by the Uniform Requirements for Manuscripts Submitted to Biomedical Journals by the International Committee of Medical Journal Editors and by the Cochrane Collaboration, and endorsed by the Annals of Internal Medicine, British Medical Journal, and Lancet. | The STROBE statement summarizes the elements an observational study manuscript should report – it is not a standard for quality assessment of observational studies. It is akin to the CONSORT statement for trials. There is no widely accepted quality assessment tool for observational studies (see AHRQ methods guide for effectiveness and comparative effectiveness reviews, Chapter 4). There are various tools for assessing the quality of observational studies and we drew from several as appropriate to this topic.
63. | 8 | Results; 1. Pp. 11-15: The discussion of surveillance did not include the population study of McMahon et al. (2000), which demonstrated a survival benefit in Alaska natives with chronic hepatitis B. | We examined the McMahon study, but it was excluded because the use of historic controls was a pre-specified exclusion criteria. This was an exclusion criterion because of the potential for additional confounding from secular trends in overall management of liver disease patients. We included a large body of observational studies and many, as we describe, found that screen-detected patients had longer survival. Whether screening truly prolonged survival or screen-detected patients appeared to live longer because of lead-time and other biases is not clear. The McMahon study would have provided findings and methodologic issues similar to the many other observational studies we examined. We did revise our presentation of observational study results in the table and narrative portions to make the precise survival data and hazard ratios easier to follow.
64. | 8 | 2 Pp. 15-8 – The conclusions regarding the effects of OLT, resection, RFA, and TACE do not reflect the following data, which were not included in the review:; a. El-Serag et al. (2006) used data on HCC patients from SEER and Medicare claims to construct a Cox proportional hazards model to identify predictors of outcome; the model incorporated tumor size and extent. The type of therapy received was a significant predictor of survival. | See #32
65. | 8 | b A similar study by Schwartz and Smith (2008), adjusting for disease extent and vascular invasion among other factors, found risk ratios of 0.56 for transplantation and 1.53 for ablation. As noted below, ablation is associated with increased survival compared to other modalities. | See #32
66. | 8 | c Although cited in this document, the data from reference 18 (Mazzaferro et al. 1996) were not compared with historic controls for early stage HCC; the survival rates in this study far exceed those observed in patients with untreated early disease (see references listed under Comment 3). | See #62
67. | 8 | d Although cited in this document, the results from reference 49 (Liu et al. 2004), which found that HCC resection was associated with a mortality reduction of 55%, are dismissed with statements about “confounding by indication” and concerns about performance status as a confounding. There is no evidence that the natural history of HCC is significantly affected by etiology (assuming that that was what the authors meant). Liu et al. excluded patients from their study who had medical contraindications to surgery, which makes confounding by performance status unlikely. | We have rewritten this part. We agree that the Liu study is probably the best of the comparative observational studies and we describe the results as low-strength evidence. As Liu et al themselves acknowledge, they did not have information on comorbidities and other confounding factors.
68. | 8 | e Cho et al. (2009) conducted a meta-analysis of trials comparing ablation with percutaneous ethanol injection in patients with early HCC and found a significant survival advantage for ablation. Similar results were obtained by Orlando et al. (2009) | See #32
69. | 8 | f Llovet et al. (2002) conducted a landmark prospective RCT comparing TACE to TAE to conservative therapy in patients with early stage HCC. TACE was associated with a significant survival benefit. | See #32
70. | 8 | 3 Page 21 – Discussion; The statement that “Our focus on studies comparing active treatment to conservative management admittedly may have missed important effects of current treatments for HCC since many have been evaluated in the context of comparative effectiveness studies” is an understatement. If there was a question about whether treatment of early HCC is effective, inclusion of controlled trials with a [underlined: superiority] design would have been absolutely appropriate. These do not represent “comparative effectiveness” studies, as suggested in the text. | See #16