# TABLES

Table 1 Randomized trials of hepatocellular carcinoma screening in patients with chronic liver disease

Table 2 Assessment of study methods for potential sources of bias in randomized trials of hepatocellular carcinoma screening

Table 3 Cohort studies of screening for hepatocellular carcinoma in patients with chronic liver disease

Table 4 Assessment of study methods for potential sources of bias in cohort studies of screening for hepatocellular carcinoma in patients with chronic liver disease

Table 5 Randomized controlled trials comparing TACE to supportive care in patients with hepatocellular carcinoma

Table 6 Assessment of study methods for potential sources of bias in randomized trials of TACE in patients with early-stage hepatocellular carcinoma

Table 7 Cohort studies comparing resection, RFA, TACE, and OLT to supportive care in patients with hepatocellular carcinoma

Table 8 Assessment of study methods for potential sources of bias in cohort studies of resection, OLT, RFA, and TACE in patients with hepatocellular carcinoma

Table 9 Non-comparative observational studies of OLT, RFA, and TACE in patients with hepatocellular carcinoma

Table 10 Summary of AASLD, APASL, and EASL-EORTC guidelines for screening for hepatocellular carcinoma

Table 11 AGREE II quality assessment of guidelines for screening for hepatocellular carcinoma