# FIGURES

Figure 1 Analytic Framework

Figure 2 Literature flow diagram

Figure 3 Median survival in cohort studies of HCC patients diagnosed through screening programs compared with non-screening

* P < 0.05

† P-value was not reported.

‡ Screening group includes patients screened at both 0-6 and 7-24 month intervals before HCC diagnosis.