# SEARCH STRATEGY

## Key Question 1 (Screening)

Medline (via PubMed) Searched 1/29/2013.

HCC | “hepatocellular carcinoma”[Title/Abstract] OR “HCC”[Title/Abstract] OR “Carcinoma, Hepatocellular”[Mesh] OR “liver cancer”[Title/Abstract] OR “Liver Neoplasms”[Mesh]
AND
Screening | “alpha-Fetoproteins”[Mesh] OR alpha-fetoprotein*[Title/Abstract] OR alfa-fetoprotein*[Title/Abstract] OR alpha-foetoprotein*[Title/Abstract] OR alfa-foetoprotein*[Title/Abstract] OR alpha-fetalprotein*[Title/Abstract] OR alfa-fetalprotein*[Title/Abstract] OR alpha fetalprotein*[Title/Abstract] OR alfa fetalprotein*[Title/Abstract] OR alphafetoprotein*[Title/Abstract] OR alfafetoprotein*[Title/Abstract] OR alphafoetoprotein*[Title/Abstract] OR alfafoetoprotein*[Title/Abstract] OR alphafetalprotein*[Title/Abstract] OR alfafetalprotein*[Title/Abstract] OR CT[Title/Abstract] OR “Tomography, X-Ray Computed”[Mesh] OR mri[Title/Abstract] OR magnetic resonance imaging[Title/Abstract] OR “Magnetic Resonance Imaging”[Mesh] OR screen-detected[Title/Abstract] OR screening[Title/Abstract] OR “Mass Screening”[Mesh] OR “Early Detection of Cancer”[Mesh] OR ultrasonography[Title/Abstract] OR “Ultrasonography”[Mesh] OR “ultrasonography”[Subheading]

## Key Question 2 (Harms of Screening)

(Note: medical adverse effects of screening would be included in above search. An additional search was designed to capture psychological harms of screening specifically.)

Medline (via PubMed) Searched 3/5/2013.

HCC | “hepatocellular carcinoma”[Title/Abstract] OR “HCC”[Title/Abstract] OR “Carcinoma, Hepatocellular”[Mesh] OR “liver cancer”[Title/Abstract] OR “Liver Neoplasms”[Mesh]
AND
Psych harms | “False Positive Reactions”[Mesh] OR “False Negative Reactions”[Mesh] OR “Anxiety”[Mesh] OR “Depression”[Mesh] OR “Stress, Psychological”[Mesh] OR “Patient Acceptance of Health Care”[Mesh] OR “psychology”[Subheading]

An additional search for psychological harms of screening was conducted in PsycInfo (via OVID) on 6/28/2013:

(((“hepatocellular carcinoma”[Title/Abstract]) OR “HCC”[Title/Abstract])) OR (“Carcinoma, Hepatocellular”[Mesh])OR((“liver cancer”[Title/Abstract])) OR (“Liver Neoplasms”[Mesh])

The search of PsycInfo yielded 160 citations; none were found to be relevant.

## Key Question 3 (Treatment)

Medline (via PubMed) Searched 3/5/2013.

HCC | “hepatocellular carcinoma”[Title/Abstract] OR “HCC”[Title/Abstract] OR “Carcinoma, Hepatocellular”[Mesh] OR “liver cancer”[Title/Abstract] OR “Liver Neoplasms”[Mesh]
AND
Treatment | ablation[Title/Abstract] OR “Ablation Techniques”[Mesh] OR hepatectomy[Title/Abstract] OR resection[Title/Abstract] OR excision[Title/ Abstract] OR “Hepatectomy”[Mesh] OR Sorafenib[Title/Abstract] OR Nexavar[Title/Abstract] OR “sorafenib”[Supplementary Concept] OR transplant[Title/Abstract] OR transplantation[Title/Abstract] OR “Liver Transplantation”[Mesh] OR treatments[Title/Abstract] OR treatment[Title/Abstract] OR “Therapeutics”[Mesh] OR “therapy”[Subheading]
AND
Mortality | mortality[Title/Abstract] OR survival[Title/Abstract] OR “Mortality”[Mesh] OR “mortality”[Subheading] OR “Survival Rate”[Mesh]

## Additional searches

The searches developed for MEDLINE were adapted for the Cochrane Central Register of Controlled Trials and searched on 6/28/2013.

ClinicalTrials.gov was searched on 9/3/2013 with the term “Hepatocellular Carcinoma” and no limitations on study type, recruitment status, etc.