# RESULTS

## LITERATURE FLOW

Figure 1 shows the flow of articles through the search and review process. The literature search identified 2627 unique citations from a combined search of MEDLINE^®^ (via PubMed^®^), Embase, CINAHL and PsycINFO. After applying inclusion and exclusion criteria at the title-and-abstract screening level, 205 full texts were retrieved for further review. Of these, 41 randomized controlled trials (RCTs) were retained for data abstraction. All 41 RCTs addressed both KQ 1 and KQ 2. Appendix B presents a study characteristics table detailing all 41 eligible RCTs included in this report.

Figure 1 Literature Flow Diagram

* Search results from PubMed (875), CINAHL (1239), Embase (450), and PsycINFO (63) were combined.

## CHARACTERISTICS OF INCLUDED STUDIES

Across the 41 included trials, the number of health coaching sessions ranged from 3 to 156 with a median of 12. Primary mode of coaching delivery was by phone in 52% of trials, followed by 28% in-person (n=9 individual and 4 group). Other coaching delivery modes were mixed (n=4), video (n=2), and web (n=2). Only one trial used a “certified” health coach.^19^ Fifty percent of trials used healthcare providers (eg, registered nurses) for coaches; 14% used peers; 11% were behavioral health providers (eg, social workers), and another 23% used other nonprofessionals who did not qualify as “peers.” In total, 37% of trials did not report the level of interventionist training. For the studies that reported level of training, regimes varied considerably across studies in detail, scope, and duration. Of the 3 prioritized key elements of coaching examined in this report, patient-centeredness was the most prevalent (68% of trials), followed by patient identification of goals (58.5% of trials) and the self-discovery process (46%). Only 14 trials contained all 3 key elements. Ten trials had active comparator arms (eg, another mode of coaching, an intensive noncoaching program), while the other 31 used inactive comparators (eg, waitlist, usual care). A search of ClinicalTrials.gov identified 2 completed but unpublished trials that we believe would meet our inclusion criteria, revealing a small degree of publication bias.

Most studies recruited populations with type 2 diabetes (n=18). The remaining studies recruited patients with mixed diagnoses of diabetes and heart disease or renal disease (n=4), obesity (n=7), or heart disease only (n=4). Other trials addressed cancer (n=2), rheumatoid arthritis (n=2), systemic lupus erythematosus (n=1), multiple sclerosis (n=1), metabolic syndrome (n=1), or chronic conditions in general (n=1). The 41 trials included 11,390 subjects (average 278, median 201, range 32 to 1835 per trial). Of the 36 trials reporting completion rates, all were above 75% except one, which was 64%.^20^ All trials reported average age, which ranged from 20.5 to 69.6 years with a median of 59.2 years. In the 40 trials reporting gender, women averaged 65% (range 15% to 100%). Race was not reported in 56% of the trials. Of the 18 trials reporting race, median was 58% white (range 0% to 99%).

Studies were conducted between 2002 and 2016 in 9 countries: 61% in the United States, 17% in Europe, and 12% in Australia. The majority (93%) were funded by government or foundations. Only one of these was a VA trial. The setting was primary care (n=18), specialty clinic (n=9), community (n=7), or other setting (n=7; eg, university, workplace). Duration of the active intervention period was reported in all but one trial^21^ and ranged from 12 to 104 weeks (median 33 weeks) with 80% of studies having an active intervention period of 6 months or longer. Only 15% trials (n=6) had a grade of low risk of bias. Over 50% of trials (n=21) received a grade of unclear risk of bias, while 34% of trials (n=14) received a grade of high risk of bias.

Table 4 describes the intervention and comparators for the 41 RCTs in alphabetical order by author. We present detailed findings following the table, organized by KQ and then by outcome of interest as follows:

- KQ 1a—Clinical health outcomes: HbA1c (n=20), cardiovascular health (n=6), and functional status (n= 2)
- KQ 1b—Patient health behaviors: physical activity (n=17), weight management (n=20), diet (n=10), smoking (n=2), and medication adherence (n=3)
- KQ 1c—Self-efficacy (n=8)
- KQ 2—Same outcomes as KQ 1, along with variations by 5 key moderators of interest:
  ○ KQ 2a—Population characteristics
  ○ KQ 2b—Dose of intervention
  ○ KQ 2c—Mode of delivery
  ○ KQ 2d—Type of individual conducting the coaching intervention
  ○ KQ 2e—Concordance with key elements

Table 4 Health Coaching Intervention Characteristics

Study Condition N Patients | Intervention | Key Health Coaching Elements | Comparator
Annesi, 2011^22^ Obesity 137 | Six 1-hour individual meetings with YMCA “Coach Approach” trained wellness specialist + at-home exercise prescription (3/week for 24 weeks for total of 72 sessions) | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | 6 individual meetings with standard-trained fitness specialist + 72 at home exercise sessions
Appel, 2011^23^ Obesity 415 | Coaching in-person (group/individual) weekly for first 12 weeks, monthly (group/individual) next 12 weeks, then either in-person or phone for last 72 weeks by trained, supervised health professional + website and email | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | (1) Coaching support delivered remotely by phone, study-specific website, and e-mail (2) Self-directed weight management using website
Blackberry, 2013^24^ Type 2 diabetes 437 | 1 in-person baseline assessment, then 8 structured phone sessions on self-management of diabetes with coaching by trained, supervised general practice nurse; written session summaries provided to patient and primary care physician | - Use of self-discovery process | After 1 in-person baseline assessment, usual care was provided including referrals to dieticians and other diabetes specialists
Bostrom, 2016^25^ Systemic lupus erythematosus 32 | (1) 0-3 months: Individual, in-person 1-hour coaching by physiotherapist at study start, 6 weeks, and 12 weeks; general education, supervised aerobic exercise, loan and use of heart rate monitor, and use of physical activity diary (2) 4-12 months: Some physical activity supervision, heart rate monitor, and diary | None | Usual care at rheumatology clinic, but patients in control group were asked not to change their activity level during the study
Brodin, 2008^26^ Rheumatoid arthritis 228 | Phone support after 1 week, moving to once monthly by physical therapist coach; physical function tests every 3 months to encourage adherence to graded activity goals, feedback given | - Patient-determined goals | Usual care (no description given other than “control group”)
Browning, 2014^27^ Type 2 diabetes 100 | Heath coaching by nurse via in-person + phone (both 2/month for first 3 months) diminishing over next 9 months; maximum contact was 19 phone and 18 in-person sessions | - Patient-centeredness; - Use of self-discovery process | Usual care provided by family physician where patients were typically referred to diabetes specialists or to Traditional Chinese Medicine practitioners
Cinar, 2014^28^ Type 2 diabetes 186 | In addition to standard health education, 2 in-person individual visits + single 10-to 20-minute phone call within first 3 weeks; 1 in-person + 1 call in next 6 months; 1 in-person + 1 call in last 6 months, for up to 7 total contacts with the behavioral health specialist coach | - Patient-centeredness | Health education consisting of 3 seminars on oral health and diabetes management
Damschroder, 2014^29^ Obesity 481 | ASPIRE-Group: Coaching via in-person 90-minute group sessions with a specially trained lifestyle coach 1/week for 3 months, then 2/month for 6 months, then 60-minute sessions 1/month for last 3 months | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | (1) ASPIRE-Phone: Coaching via phone for 30 minutes, 1 time/week for 3 months, then 20 minutes for remaining time (2 times/month for 6 months decreasing to 1 time/month for last 3 months) (2) Standard VA MOVE! program
Frosch, 2011^21^ Type 2 diabetes 201 | Phone coaching by trained nurse diabetes educator, 5 sessions total: first session for 60 minutes; sessions 2-3 for 30 minutes, sessions 4-5 for 15 minutes | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | Education brochure on diabetes management; no other strategies employed
Glasgow, 2003^30^ Type 2 diabetes 320 | Internet-based basic information + either (1) tailored self-management (computer-mediated access to trained professional coach approximately twice weekly or (2) peer support via online forum and newsletters | - Patient-centeredness; - Patient-determined goals | In-home training to use website providing chronic disease education without additional support
Hawkes, 2013^31^ Colorectal cancer 410 | 11 health coaching sessions biweekly for 5 months via phone by nurse, behavioral specialist, or health educator (average duration of call, 31.5 minutes) + handbook + motivational postcards + pedometer | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | Usual care + educational brochures on understanding colorectal cancer, cutting cancer risk, diet, and physical activity + quarterly mailed educational newsletter
Holland, 2005^32^ Mixed (at least one chronic condition, unspecified) 504 | In-person meeting with nurse at baseline and 6 months, minimum 4 health coaching calls in between, 12 monthly newsletters, and fitness program; if depressed, patients also met with social worker | - Patient-centeredness | Usual care; controls were not recontacted by the program until the anniversary date of their initial interview for follow-up
Karhula, 2015^33^ Mixed (type 2 diabetes and cardiovascular) 250 | One coaching phone call from employee trained in Pfizer coaching model every 4-6 weeks (target=12 total); length of call approximately 30 minutes and emphasized problem-solving skills + monitoring of weight, blood glucose, SBP, and/or step count dependent on diagnosis via mobile application | None | Usual care; no further details or description of control group given
Kim, 2015^34^ Type 2 diabetes 209 | Six 2-hour group sessions over 6 weeks, then monthly coaching calls for 1 year from trained nurses or community health workers; calls ranged 15-45 minutes | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | Waitlist; no further details given
Knittle, 2015^35^ Rheumatoid arthritis 78 | 2 in-person, individual coaching sessions with rheumatology nurse, 40-60 minutes, at weeks 4 and 5; 3 followup phone calls, 20 minutes, weeks 6, 12, and 18 | - Patient-determined goals; - Use of self-discovery process | Education via 1 in-person group session with nurse
Lin, 2013^16^ Hypertension 574 | Weekly small groups for 20 weeks with trained health educators and dieticians + manual; strategies to manage weight and blood pressure via DASH diet, increase exercise; and coaching strategies; during and after group intervention, a peer educator phoned participants monthly for a total of 18 calls | - Patient-determined goals; - Use of self-discovery process | Usual care was an individual visit with interventionist to receive advice + written materials on lifestyle modification for blood pressure control consistent with JNC-7 guidelines
Luley, 2014^36^ Metabolic syndrome 184 | 1 basic education session + monthly health coaching call from trained physician or nurse, each approximately 20 minutes + accelerometer (data transmitted to coach as basis for phone calls) | None | 1 basic education session that included an explanation of importance of physical activity and diet
Ma, 2013^37^ (Companion study, Azar, 2013^38^) Obesity 241 | Lifestyle Balance of 2 weekly, in-person group sessions (90-120 minutes) using goal-setting, with food tastings and 30-45 minutes of guided exercise led by coach-dietician followed by 12-month maintenance phase; personalized email from coach monthly | - Patient-determined goals | (1) Self-led via DVD and email correspondence with coach/RD that used goal-setting, self-monitoring, and chronic disease education (2) Usual care; no further details given
McMurray, 2002^39^ End-stage renal disease with type 1 or 2 diabetes 83 | Minimum of monthly (for peritoneal patients) in-person, individual sessions with diabetes care manager for motivational coaching; weekly contact as needed by phone with manager, social worker, registered dietician, or registered nurse to cover self-management and diabetes care; maximum of 3 times/week (for hemodialysis patients) for 12 months | None | Usual care at a standard dialysis unit
Nishita, 2013^40^ Type 2 diabetes 190 | Average of ten 1-hour in-person, individual sessions with certified health coach and four 45-minute sessions with pharmacist over intervention year | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | Usual care
Patja, 2012^41^ Mixed (congestive heart failure and type 2 diabetes) 1129 | Monthly phone calls with nurse coach (initial duration averaging 60 minutes, decreasing to 30 minutes over time); call completion averaged 10-11 calls over year; optional follow-up calls were rarely used | - Patient-determined goals | Usual care
Pearson, 2013^19^ (Companion study, Pearson 2012^42^) Obesity 45 | Phone coaching sessions with certified health coach 1/week for 12 weeks; average length of call was 45 minutes | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | Scripted education-based phone lessons using cognitive behavioral therapy principles from LEARN manual 1/week for 12 weeks; average length of call was 30-45 minutes
Pinto, 2015^43^ Breast cancer 76 | Health coaching by peer educator via phone 1/week for 12 weeks; average call length was 18 minutes + pedometer + heart rate monitor + physical activity tipsheets | - Patient-centeredness | Attention control: phone contact with peer educator 1/week for 12 weeks, but topics centered on breast cancer, not physical activity
Ruggiero, 2010^44^ Type 2 diabetes 100 | 2 in-person, individual contacts (<30 minutes) with certified medical assistant trained in diabetes self-care coaching at baseline and 3 months + 4 monthly phone contacts (<15 minutes) in between clinic visits | - Patient-centeredness | Usual care with physician + basic diabetes education handbook developed by health system staff
Ruggiero, 2014^20^ Type 2 diabetes 266 | Quarterly in-person, individual coaching sessions with specially trained certified medical assistants for 30 minutes at clinic appointments; up to 8 monthly phone calls, 15 minutes, between in-person contacts | - Patient-centeredness; - Patient-determined goals | Enhanced treatment as usual; quarterly physician check-ups; referrals to specialty care (eg, podiatrist, endocrinologist) when necessary; basic education provided by “Diabetes: You're in Control” educational booklet
Sacco, 2009^45^ Type 2 diabetes 62 | Coaching call weekly for 3 months (from supervised psychology undergraduate), then every other week for 3 months; average duration of initial call was 54 minutes decreasing to 15-20 minutes | - Patient-centeredness; - Patient-determined goals | Control group received treatment as usual from a board-certified endocrinologist
Safford, 2015^46^ Type 2 diabetes 360 | 1-hour group diabetes education class + one 5-10 minute individual counseling session to go over baseline “diabetes report cards,” then peer coaches phoned weekly for the first 2 months and at least monthly for the next 8 months | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | 1-hour group diabetes education class + 5-10 minute counseling session on a “diabetes report card” showing baseline labs at enrollment
Sandroff, 2014^47^ Multiple sclerosis 76 | Coaching (discipline of coach not reported) via internet and 15, one-on-one video sessions (eg, Skype) for 6 months decreasing in frequency over time (from weekly to monthly) | - Patient-determined goals | Waitlist
Sherwood, 2010^48^ Obesity 63 | 2 active arms (same intervention for different durations: 10 sessions or 20 sessions) providing weekly telephone calls with coach (discipline not reported) lasting about 10-20 minutes + pedometer + logbook; calls followed a prescribed sequence in study manual adapted to fit into 10 or 20 lessons | Not reported | Self-directed program participants were sent copy of manual, pedometer and logbook but were not recontacted until time for follow-up measures
Thom, 2013^49^ (Companion study, Moskowitz, 2103^50^) Type 2 diabetes 299 | 12-14 sessions of coaching by a peer educator (individual or phone at discretion of subject) with goals of phone contact at least twice/month and 2 or more in-person contacts over 6 months | - Patient-centeredness | Usual care included all services normally available, including a nutritionist and diabetes educator via referral from their primary care physician
Turner, 2012^51^ Hypertension 280 | Phone calls every other month at 1, 3, and 5 months (duration not reported); on alternate months (2 and 4), office-based, in-person, individual counseling sessions (15-30 minutes each) with a peer educator as coach | - Patient-centeredness; - Use of self-discovery process | Usual care at urban academic general medicine practices
Vale, 2002^52^ Cardiovascular disease 219 | 5 coaching phone calls from dietician, with first call within 2 weeks of randomization; then 3 calls, one every 6 weeks; the fifth call at 24 weeks (to schedule the 6-month assessment); duration of calls varied | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | Usual care; no further details given
Vale, 2003^53^ Coronary artery disease, cardiovascular disease 792 | 5 coaching phone calls from nurse or dietician, with first call within 2 weeks of randomization; then 3 calls, one every 6 weeks; the fifth call at 24 weeks (to schedule the 6-month assessment); duration of calls varied | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | Usual care; no further details given
Van der Wulp, 2012^54^ Type 2 diabetes 119 | 3 in-person, individual health coaching sessions, monthly, with trained peer educator using goal setting; duration of session not reported | - Patient-centeredness; - Patient-determined goals | Usual care from general practitioner based on the Dutch guidelines for type 2 diabetes
Varney, 2014^55^ Type 2 diabetes 94 | Initial coaching call within 2 weeks of randomization followed by at least monthly phone calls (range 4-9 sessions) from dietician coach; duration average 45 minutes initially, then 20 minutes for follow-up calls | - Patient-centeredness | Control group accessed usual care services, including a diabetes clinic staffed by endocrinologists, diabetes educators and dietitians; patients typically attend the clinic at least monthly, with general practitioner visits occurring as needed
Wadden, 2011^56^ Obesity 390 | (1) Coaching only: primary care visits plus 10-15 minute in-person, individual coaching sessions; 2 during the first month, then monthly for 11 months with a trained medical assistant; in months 13-24, coaching could be done by phone every other month (2) Enhanced coaching: as above + choice of meal replacements or weight loss medication | None | Usual care consisting of quarterly primary care visits that included education about weight management for 5-7 minutes each visit
Wayne, 2015^57^ Type 2 diabetes 131 | Weekly health coach sessions + exercise education program [underlined: with] smartphone wellness mobile application; components included support for health goals and goal achievement; self-monitoring; discussion of meals, exercise, blood glucose and mood; duration of session 37 (± 22) minutes/week; also health coach co-monitored patient's input to mobile application | - Patient-centeredness; - Patient-determined goals | Weekly health coach sessions + exercise education program [underlined: without] smartphone application; components included support for health goals and goal achievement; self-monitoring; discussion of meals, exercise, blood glucose, and mood; session duration 39 (±28) minutes/week
Whittemore, 2004^58^ Type 2 diabetes 53 | 6 in-person, individual coaching sessions with a trained nurse: first 3 every 2 weeks; then 2 monthly; last session 3 months after first 5 sessions with phone contacts in between sessions 5 and 6 | - Patient-centeredness; - Patient-determined goals | Standard diabetes care, defined as regular visits with a primary care physician at approximately 3- to 4-month intervals
Willard-Grace, 2015^59^ (Companion study, Thom, 2015^60^) Mixed (type 2 diabetes, hypertension, elevated lipids) 441 | 5 in-person, individual coaching sessions at baseline, 3, 6, 9, and 12 months with a trained medical assistant as well as monthly follow-ups by phone; total 16 sessions | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | Patients randomized to usual care had access to any resources available at the clinic, including visits with their clinician, diabetes educators, nutritionists, chronic care nurses, and educational classes
Wolever, 2010^61^ Type 2 diabetes 56 | 8 calls weekly for first 2 months, then 4 calls biweekly for 2 months; final call 1 month later for total of 14, 30-minute sessions with a trained social worker or medical assistant in psychology coach | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | Usual care; randomized to the control group received no materials or correspondence during the 6-month period
Young, 2014^62^ Type 2 diabetes 101 | 1 in-person, individual session with a nurse coach followed by 5 health coaching sessions via phone or videoconferencing, about once every 2 weeks; average duration of sessions was 30 minutes | - Patient-centeredness; - Patient-determined goals; - Use of self-discovery process | Usual care consisted of the services and care available at the rural clinic where the participant received healthcare

## KEY QUESTION 1 Among adults, what is the effectiveness of health coaching on a. Clinical health outcomes (eg, HbA1c, blood pressure) b. Patient health behaviors (eg, physical activity, weight management, diet, smoking, medication adherence) c. Self-efficacy

### Key Points

- Results were mixed for the impact of health coaching on a variety of clinical health outcomes. Health coaching demonstrated a small, positive, statistically significant effect on change in HbA1c (-0.30; 95% CI -0.50 to -0.10) compared with an inactive comparator. These findings did not hold when compared with active comparators. For other outcomes related to cardiovascular disease and functional status, results were inconsistent.
- For trials that reported the impact of health coaching on patient health behaviors, results also were inconsistent:
  ○ Physical activity: We found a small, positive, statistically significant effect of health coaching on physical activity measured as a continuous variable in steps or minutes compared with an inactive control; when compared with active controls, the estimate was not significant. There was no difference between groups in studies that measured physical activity as reaching or exceeding some threshold.
  ○ Weight management: We found a small, positive, statistically significant effect of health coaching on reductions in BMI compared with an inactive control. Only 2 studies had active comparators and neither of these had statically significant effects.
  ○ Diet: There were consistent small, positive effects of health coaching on decreasing fat intake in quantitative analysis and total calories in qualitative synthesis. Results were mixed for any effect of health coaching on fruit and vegetable intake, and only one study found a positive effect on diet adherence.
  ○ Smoking: Only 2 trials measured the impact of health coaching on smoking behavior; smoking cessation was only one of a number of health behaviors addressed in both trials. Neither trial found an effect of health coaching on self-reported smoking cessation.
  ○ Medication adherence: Three trials examined the impact of health coaching on medication adherence outcomes, and only one of these found that health coaching was associated with a significant improvement in medication adherence.
- For self-efficacy, when stratified by type of comparator, a statistically significant, small-to-moderate positive effect was found for health coaching interventions on self-efficacy when compared with inactive controls. Only one study compared health coaching with an active control. This effect size was also positive and statistically significant.
- A high risk of bias (ROB) and heterogeneity limit certainty about the interpretation of our findings.

For KQ 1, we present detailed findings on the effects of health coaching on clinical health outcomes (KQ 1a), patient health behaviors (KQ 1b), and self-efficacy (KQ 1c).

### Detailed Findings for Clinical Health Outcomes (KQ 1a)

In this section, we describe findings by effects on HbA1c, cardiovascular health (systolic blood pressure, cholesterol), and functional status.

#### Effects on HbA1c

Twenty of the eligible RCTs examined the impact of health coaching on HbA1c in patients with diabetes.^20,21,24,27,28,30,33,34,39-41,44-46,49,55,57-59,61^ Table 5 summarizes key elements of the 20 studies.

Table 5 Evidence Profile of Studies Reporting Change in HbA1c

Number of trials: 20 published 2002-2015. Number of participants: 5850 total (average/trial=308, range 53 to 1835). Setting: Most participants were recruited from primary care (n=10); remaining studies were conducted in a variety of specialty care settings or recruited directly from the community. Countries: 6 countries were represented (Australia, Canada, China, Finland, Turkey, and USA; 60% were conducted in the USA); 1 study did not report country. Key elements of health coaching: Patient-centeredness was reported in 42% of studies, patient-determined goals reported in 31.6%, and self-discovery process reported in 21%; 1 study did not report any of the key elements. Comparisons: Most studies (n=18) compared health coaching with usual care, waitlist, or some other form of unenhanced control. Measurement of outcomes: All studies reported change in HbA1c outcomes. Risk of bias: 1 study was rated as low ROB; 12 unclear ROB; and 7 high ROB.

Of the 20 trials, all but one^41^ measured HbA1c as a continuous variable; this study categorized HbA1c as a dichotomous variable (in or out of control) and could not be included in the meta-analysis. We stratified results by comparator type (inactive vs active) and present stratified and overall pooled estimates. An inactive comparator group was used in 17 trials; 1 trial was rated as low ROB,^24^ 12 as unclear ROB,^21,27,28,33,39,40,44,45,49,57,59,61^ and 7 as high ROB.^20,30,34,41,46,55,58^ An active comparator group (such as another type of health coaching) was used in only 2 studies.^30,57^ Thus, we could not produce a pooled estimate. Figure 2 shows the forest plot examining the effect of health coaching on HbA1c. The pooled estimate indicated a statistically significant effect for health coaching interventions on HbA1c when compared with an inactive comparator (ΔA1c -0.30; 95% CI -0.50 to -0.10). This summary estimate had high heterogeneity (I^2^=65.5%).

Figure 2 Effect of Health Coaching on HbA1c

Abbreviations: CI=confidence interval; SD=standard deviation

We identified 3 additional trials that examined the effect of health coaching on HbA1c.^30,41,57^ Results were null in all 3 studies. In contrast to the pooled analysis, 1 study^41^ compared a phone-based coaching intervention with usual care and found no significant difference in proportion of patients achieving A1c <7.0%. The other 2 studies compared health coaching with a more robust, active comparator. One trial^57^ compared a health coaching intervention with a more intensive coaching intervention that involved real-time, on-demand access to the coach through a phone application; this study showed no significant difference between the 2 coaching interventions. Another trial^30^ compared a tailored self-management coaching intervention to a peer support group and found no difference between these 2 active arms.

#### Effects on Cardiovascular Health

Six of the eligible RCTs examined the impact of health coaching on one or more cardiovascular outcomes across these chronic disease conditions: cardiovascular disease, hypertension, coronary artery disease or congestive heart failure, or a mixture of conditions.^16,41,51-53,59^ Findings are grouped by systolic blood pressure and cholesterol. Table 6 summarizes key elements of the 6 studies.

Table 6 Evidence Profile of Studies Reporting Change in Cardiovascular Health

Number of trials: 6 published 2002-2015. Number of participants: 4167 total (average/trial=595, range 245 to 1835). Setting: Most participants were recruited from primary care (n=4), with the remaining (n=2) from a specialist cardiology clinic. Countries: 3 countries were represented (Australia, Finland, and USA; 50% were conducted in the USA). Key elements of health coaching: Patient-centeredness was reported in 44.4% of studies; self-discovery process reported in 44.4%, and patient-determined goals reported in 31.6%; 11.1% did not report any key element. Comparisons: All 6 studies compared health coaching with usual care. Measurement of outcomes: Most studies (n=5) reported systolic blood pressure; 1 study reported LDL cholesterol, 1 reported total cholesterol, and 1 reported Framingham risk score. Risk of bias: 3 studies were rated as low ROB and 3 as unclear ROB.

##### Systolic Blood Pressure

Five of the 6 trials examined the effect of health coaching on systolic blood pressure.^16,41,51,53,59^ One trial, rated as low ROB,^16^ targeted patients with hypertension and compared the effects of small-group, in-person health coaching focused on dietary behavior change with a physician-focused quality improvement intervention. This study found that patients who received health coaching had a 2.6mmHg drop in systolic blood pressure (95% CI -4.4 to -0.7; p=0.01) at 6 months, although this change did not persist at 18 months. Another trial rated as low ROB^51^ compared a mixed intervention of phone and in-person individual counseling with usual care. This study found that at 6 months, patients who completed the coaching intervention had a 6.4-mmHg reduction in systolic blood pressure compared with the control group. Three additional trials were of mixed quality (high or unclear ROB) and concluded that health coaching was not associated with a significant reduction in blood pressure.^41,53,59^ Two of these focused on patients with heart disease^41,53^ while the third focused on a mixed population of participants with uncontrolled diabetes, hypertension, or hyperlipidemia.^59^

##### Cholesterol

Four of the 6 trials examined the effects of health coaching on cholesterol (total cholesterol or LDL).^41,52,53,59^ Of these, 1 was rated as low ROB,^53^ 2 as unclear ROB,^52,59^ and 1 as high ROB.^41^ These studies produced mixed findings, with most reporting no statistical or clinically significant effects of health coaching on cholesterol. The trial rated as low ROB^53^ recruited patients immediately following revascularization procedures and compared personalized phone-based health coaching to usual care for changes in cholesterol. This study found that at the 6-month follow-up, patients who received health coaching had a 14mg/dL (0.36mmol/L) greater drop in mean total cholesterol level compared with those who received usual care (0.328mmol/L to 0.163mmol/L; p <0.02).

One trial rated as unclear ROB^59^ examined the proportion of patients meeting cholesterol-reduction goals in a health coaching intervention for a mixed population. No significant difference was found between the health coaching (43%) and the usual care groups (37%) (95% CI -4 to 25, p=0.15). The second trial rated as unclear ROB^52^ found a positive effect of health coaching on mean cholesterol level in the health coaching group compared with control (5.0mmol/L vs 5.54mmol/L; p<0.0001) as well as LDL cholesterol (3.11 vs 3.57; p=0.0004); no positive effect was found on HDL cholesterol. The trial rated as high ROB^41^ compared phone-based health coaching with usual care in patients with coronary artery disease or congestive heart failure. This study found that cholesterol-reduction goals were achieved more often in the health coaching arm compared with the control arm, yet there were no significant reductions in cholesterol endpoints between the 2 groups.

#### Effects on Functional Status

Two of the eligible RCTs examined the impact of health coaching interventions on functional status compared with inactive controls.^35,47^ One study was rated as unclear ROB^35^ and one as high ROB^47^; results were mixed. Both coaching interventions sought to increase physical activity in individuals with physically disabling conditions, rheumatoid arthritis,^35^ and multiple sclerosis,^47^ and also assessed the impact of health coaching on functional status. The trial with unclear ROB (n=78) investigated the effect of six 2-hour group sessions over 6 weeks, then monthly coaching calls for 1 year, by trained nurses or community health workers compared to an education control with one nurse-led group session in individuals with rheumatoid arthritis.^35^ Functional status was measured using the 20-item disability scale of the Health Assessment Questionnaire. No differences were found between groups in functional status postintervention (Cohen's d=0.03) or at a 32-week follow-up (Cohen's d=0.04). The trial with high ROB (n=76) explored the impact of 15 one-on-one coaching sessions via Skype over 6 months compared to waitlist control in individuals with multiple sclerosis.^47^ This trial used an objective measure, the 6-minute walk test, to assess changes in functional status. At the end of the 6-month intervention, the intervention group demonstrated improvements in self-reported physical activity and an increased 6-minute walk distance (partial-η^2^ = 0.07) compared with the control group.

### Detailed Findings for Patient Health Behaviors (KQ 1b)

In this section, we describe findings by effects on physical activity, weight management, diet, smoking, and medication adherence.

#### Effects on Physical Activity

Seventeen of the eligible RCTs examined the impact of health coaching on physical activity across these chronic disease conditions: type 2 diabetes (n=8), cancer (n=2), obesity (n=2), rheumatoid arthritis (n=2), systemic lupus erythematosus (n=1), multiple sclerosis (n=1), or a mixture of chronic diseases (n=1).^20,21,25,26,29-32,35,43,45,47,48,54,55,58,61^ Table 7 summarizes key elements of the 17 studies.

Table 7 Evidence Profile of Studies Reporting Change in Physical Activity

Number of trials: 17 published 2003-2016. Number of participants: 3119 total (average/trial=183, range 32 to 504). Setting: Most participants were recruited from primary care (n=5) or specialty clinics (n=5), with a few studies recruiting from the community, university, registry, or a combination; only 1 study recruited from a VA clinic. Countries: 4 countries were represented (Australia, the Netherlands, Sweden, and USA; 65% were conducted in the USA). Key elements of health coaching: Patient-centeredness and patient-determined goals were equally prominent in the studies (70.5%), while self-discovery process was reported in 29%. Comparisons: 4 studies had active comparators: 2 provided coaching via another mode; 1 provided all the same materials but was self-directed, and 1 provided an attention control around other aspects of the condition; the other 13 trials used usual care, education, or waitlist. Measurement of outcomes: The primary physical activity outcome was self-reported in 16 studies using multiple questionnaires; 1 study used an objective measure in the form of a pedometer as the primary measurement; 1 study validated a self-report questionnaire with measured or imputed accelerometer results. Risk of bias: 1 study was rated as low ROB, 7 as unclear ROB, and 9 as high ROB.

Two studies measured physical activity as a categorical variable and 15 measured the outcomes as a continuous variable. Of the 15 trials that were amenable to quantitative synthesis, however, physical activity was measured in 2 conceptually distinct ways. Thus we separated the 15 trials into 2 groups: (1) 10 studies that measured physical activity as a continuous variable using metrics such as steps/day or minutes/day or week, which hereafter is called “physical activity change”^29-32,35,43,47,48,55,58^ and (2) 5 studies that measured physical activity as a continuous variable above some cut-off threshold (eg, 30 minutes of activity/day), which hereafter is called “physical activity threshold.”^20,21,45,54,61^ These 2 approaches to the measurement of physical activity were considered different enough to require separate meta-analyses. In addition, within each of these broad categories, there was substantial variability in the mode and metrics of scales used to measure physical activity. Therefore, all summary estimates were calculated as standardized mean differences (SMDs). Last, we provide a qualitative description of findings for the 2 trials that could not be pooled with the other studies.

##### Physical Activity Change

The 10 trials evaluated in the physical activity change meta-analysis comprised 6 inactive comparators^31,32,35,47,55,58^ and 4 active comparators.^29,30,43,48^ The 6 trials in the inactive group contained 1215 participants and were judged either unclear (n=3) or high (n=3) ROB. The 4 trials in the active group contained 940 participants and were all judged as high ROB. Figure 3 shows the forest plot examining the effect of health coaching on physical activity change stratified by inactive and active comparator subgroups. When compared with inactive controls, the pooled estimate demonstrated a small positive effect of health coaching interventions on physical activity change that was statistically significant (n=6; SMD 0.29; 95% CI 0.15 to 0.43). This summary estimate exhibited no heterogeneity (I^2^'d=0.0%). This effect disappeared when health coaching was compared with active controls (n=4; SMD 0.17; 95% CI -0.32 to 0.67). This summary estimate showed moderate heterogeneity (I^2^'d=53.2%).

Figure 3 Effect of Health Coaching on Physical Activity Change

Abbreviations: CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

Three trials that examined the effect of health coaching on physical activity change had more arms than were included in the meta-analysis.^29,30,48^ These were all conducted in the United States on populations with obesity^29,48^ or diabetes.^30^ All trials were judged as high ROB and had active control groups. The first study on obesity (n=481)^29^ examined a second mode of coaching (via the phone) versus in-person group coaching or the VA's weight control program, MOVE!, over a year. The second study on obesity (n=63)^48^ examined a second coaching duration length (10 weeks instead of 20 weeks) versus a self-directed control group, all using the same study materials with follow-up at 6 months. The study on diabetes (n=320)^30^ examined a second mode of coaching (from a peer rather than a professional) versus self-directed access to all materials via the internet. However, none of these additional comparisons showed any statistically significant differences between groups, in keeping with the result of the meta-analysis for active comparators (Figure 3 above).

##### Physical Activity Threshold

The 5 trials evaluated in the physical activity threshold meta-analysis all used inactive comparators.^20,21,34,45,54,61^ These trials contained 711 participants and were judged either unclear (n=3) or high (n=2) ROB. Figure 4 shows the forest plot examining the effect of health coaching on physical activity threshold. The pooled estimate demonstrated a small positive effect of health coaching interventions on physical activity threshold when compared with inactive controls, but it was not statistically significant (n=5; SMD 0.33; 95% CI -0.54 to 1.19). This summary estimate exhibited high heterogeneity (I^2^'d=87.9%).

Figure 4 Effect of Health Coaching on Physical Activity Threshold

Abbreviations: CI=confidence interval; SMD=standardized mean difference

##### Qualitative Findings for Physical Activity

Two of the 17 RCTs examining the effect of health coaching on physical activity could not be pooled with the other studies.^25,26^ One was rated as low ROB^25^ and the other as high ROB.^26^ These trials were conducted in populations with rheumatoid arthritis (n=228)^26^ or systemic lupus erythematosus (n=32)^25^ and were majority or entirely female. Both trials examined categorical variables: attainment of a “healthy” goal (moderate to high intensity physical activity 4 times/week) or a specific frequency category for high or moderate-to-high intensity physical activity versus usual care. Both interventions lasted 1 year. One intervention^26^ was monthly coaching by phone. The other^25^ consisted of coaching every 6 weeks for 3 months decreasing over time. In addition, participants received supervised exercise, a heart rate monitor and a physical activity diary. Despite differences in study size, quality, and intervention intensity, neither study found any significant differences in physical activity between intervention and control groups. One possible reason might be the high exercise intensity level set for reaching the goal or moving between categories, which would be difficult to attain for these populations.

#### Effects on Weight Management

Twenty of the eligible RCTs examined the impact of health coaching on weight as measured in changes in pounds or kilograms (n=12), body mass index (BMI) (n=16), or both pounds/kilograms and BMI (n=8).^19,21,23,24,27,29,31-33,36,37,40,46,48,49,53,55-58^ These RCTs examined the impact of health coaching on weight management across the following chronic disease conditions: type 2 diabetes (n=9); obesity (n=6); metabolic syndrome (n=1); colorectal cancer (n=1); cardiovascular disease (n=1); mixed chronic disease conditions (n=1); and one study that contained 2 study subgroups of type 2 diabetes and cardiovascular disease. Table 8 summarizes key elements of the 20 studies.

Table 8 Evidence Profile of Studies Reporting Weight Management Outcomes

Number of trials: 20 published 2003-2015. Number of participants: 5640 total (average/trial=282, range 45 to 792). Setting: Most participants were recruited from primary care (n=8) or community clinics (n=4); others from a cancer registry (n=2), specialty clinic (n=2), general outpatient clinic (n=1), community/university (n=1), community/work place (n=1), university only (n=1), and VA setting (n=1). Countries: 6 countries were represented (Australia, Canada, China, Finland, Germany, USA; 55% were conducted in the USA). Key elements of health coaching: Patient-centeredness was reported in 70% studies; self-discovery process and patient-determined goals were equally prominent (50% and 55% of the studies, respectively); 20% of studies provided no information on any key elements. Comparisons: 6 studies compared health coaching with active comparators; the remaining 14 used usual care, treatment as usual, education, or waitlist. Measurement of outcomes: Measure of weight management/change in pounds/kilograms was reported in 12 studies, BMI was reported in 16 studies, and 8 studies reported both. Risk of bias: 3 studies were rated as low ROB, 10 as unclear ROB, and 7 as high ROB.

As change in BMI was the most common metric across the 20 studies, we conducted a quantitative synthesis by this outcome. Sixteen of the 20 trials reported change in BMI and were amenable to quantitative synthesis. We stratified results by comparator type (inactive vs active) and present stratified and overall pooled estimates when feasible. Last, we provide a qualitative synthesis of findings for the 4 trials that reported outcomes as change in kilograms or pounds only and could not be pooled with the other studies.

The 16 trials that explored the impact of health coaching on BMI contained 4021 participants and were judged either low (n=2), unclear (n=9), or high (n=5) ROB. Figure 5 shows the forest plot examining the effect of health coaching on change in BMI. The pooled estimate demonstrated a positive effect of health coaching interventions when compared with inactive controls (n=14; MD -0.52; 95% CI -0.91 to -0.14). This summary estimate exhibited high heterogeneity (I^2^=68.5%).

Figure 5 Effect of Health Coaching on BMI

##### Qualitative Findings for BMI

Five trials that examined the effect of health coaching on BMI change had more coaching-related arms than were included in the meta-analysis (n=3^23,29,56^) or compared health coaching with more robust, active comparators (n=1^57^), and could not be included in the summary estimate with the inactive comparators. One 2-arm trial of unclear ROB^57^ compared a health coaching intervention with a more intensive coaching intervention that involved real-time, on-demand access to the coach through a phone application for patients with diabetes; this study showed no significant difference between the 2 coaching interventions.

The other 3 remaining trials with more than 2 coaching-relevant arms were all conducted among populations with obesity. Results were mixed. The first 3-arm study^23^ compared in-person coaching with phone-delivered coaching or usual care. In both coaching arms, the frequency of the interventions was the same (12 weekly coaching sessions followed by monthly coaching session for the duration of the 24-month intervention). Both coaching arms produced the same statistically significant reduction in BMI compared with usual care (1.7 vs 0.4 decrease in BMI; p-values not reported). This trial was rated as unclear ROB. Another study rated as unclear ROB^56^ compared usual care with brief monthly lifestyle coaching with or without meal replacement or weight loss medications. (Figure 5 above displays the contrast between usual care and the brief lifestyle coaching without meal replacement condition.) There were no significant differences between arms on change in BMI. Last, one 3-arm study at high ROB^29^ examined a second mode of coaching (via the phone) versus in-person group coaching or the VA's MOVE! weight control program over a year among Veterans with obesity. Participants in all three groups achieved statistically significant reductions in BMI at 12 months. Group coaching outperformed both MOVE! and phone coaching, but the contrast with MOVE! was not statistically significant (Figure 5).

##### Qualitative Findings for Weight Management in Pounds or Kilograms Only

There were 4 studies conducted in North America, Scandinavia, or Australia that presented data on change in pounds/kilograms but not BMI.^19,24,33,48^ These findings are synthesized qualitatively. All 4 health coaching interventions were delivered via telephone. Two studies were conducted in patients with obesity, one was conducted in patients with type 2 diabetes, and one study looked at the effect of the same intervention on 2 populations, one with type 2 diabetes and one with cardiovascular disease (CVD).

The 2 obesity studies had conflicting results: one study with high ROB^48^ showed a positive effect of health coaching, while the other study with high ROB^19^ showed a positive effect for the active control group. The latter study^19^ assessed the effect of weekly health coaching sessions that emphasized motivational interviewing versus structured lifestyle change instruction over 12 weeks. The noncoaching lifestyle change arm decreased weight more (-3.5 kg vs -1.1 kg, p=0.01) at post-intervention than the coaching arm. However, there was a 73% dropout rate among these participants. The other study^48^ assessed 3 groups, 2 of which received weekly phone calls from a coach, either 10 or 20 sessions, over 6 months. The control group received all of the materials—an instructional manual, a pedometer, and a log book for self-monitoring—but did not receive any personal contact. On average, the 20-call group lost twice as much weight as the self-directed group (-4.9 kg vs -2.3 kg), while the average weight loss of the intermediary 10-call group was -3.2 kg (p values not given).

Neither diabetes study, one with low ROB^24^ and one with unclear ROB,^33^ found positive effects on weight loss in kilograms for health coaching versus an inactive control. The latter study,^33^ which also looked at CVD, did not find a positive effect of health coaching. The diabetes studies^24,33^ had inactive, usual care control groups, used change in weight (kg) as a secondary outcome, and had completion rates over 90%. One study^24^ was a cluster RCT (n=473 from 30 primary care practices, mean age 47 to 48, 30% women) that assessed the effect of 8 nurse-led, structured health coaching sessions via phone over 18 months. They found no significant difference in weight between groups (p=0.89); however, the median number of sessions received was only 3 (interquartile range, 1 to 5). The other study^33^ used the same intervention on 2 populations, diabetes (n= 250, mean age 66 years, 49% women) and CVD (n=267, mean age 69 years, 44% women). The intervention consisted of a 30-minute phone call from a trained health coach every 4 to 6 weeks over 12 months. They found no significant difference in weight between groups in either population.

#### Effects on Diet

Eleven of the eligible RCTs examined the impact of health coaching on an outcome related to diet for these chronic disease conditions: type 2 diabetes (n=6), obesity (n=2), cancer (n=1), hypertension (n=1), and coronary heart disease (n=1).^16,19-21,29-31,45,53,54,58^ Table 9 summarizes key elements of the 11 studies.

Table 9 Evidence Profile of Studies Reporting Change in Diet

Number of trials: 11 published 2003-2014. Number of participants: 3325 total (average/trial=302, range 45 to 792). Setting: Most participants were recruited from primary care (n=6); other from community/university (n=1), cancer registry (n=1), cardiology clinic (n=1), outpatient diabetes education setting (n=1), and VA setting (n=1). Countries: 4 countries were represented (Australia, Canada, Netherlands, and USA; 64% conducted in the USA). Key elements of health coaching: Patient-determined goals and patient-centeredness were reported in 100% and 91% of the studies, respectively; self-discovery process was reported in 55%. Comparisons: 3 studies had active comparators: 1 used the VA MOVE program, 1 used in-home training to use a website providing chronic disease education without addition support, 1 used scripted education-based phone lesson principles from the LEARN manual; 8 used inactive comparators described as enhanced treatment as usual, usual care, treatment as usual, or education alone. Measurement of outcomes: 6 studies reported some type of adherence to diet measure, 5 studies reported fruit and/or vegetable intake, 3 reported the Summary of Diabetes Self-care Activities diet subscale, 6 reported some type of fat-intake change, 2 reported kcal or energy intake, and 1 reported on dietary fiber intake. Risk of bias: 2 studies were rated as low ROB, 4 as unclear ROB, and 5 as high ROB.

Two studies were rated as low ROB,^16,53^ 4 as unclear ROB,^21,31,45,54^ and 5 as high ROB.^19,20,29,30,58^ Of the 11 studies, which examined the outcome of diet as a continuous variable, 10 were amenable for quantitative synthesis. There was substantial variability in the mode and metrics of scales used to measure diet. Therefore, we conceptualized change in diet as one of the following 4 types of outcomes: (1) adherence to some sort of prespecified diet plan,^16,20,21,30,45,58^ (2) change in dietary fat consumption,^16,29-31,53,54^ (3) change in total calories,^16,19^ or (4) change in fruit and vegetable consumption.^16,19,20,29,31^ Due to the variability in measurement, all summary estimates were calculated as SMDs. We stratified results by comparator type (inactive vs active) and present stratified pooled estimates.

##### Adherence to a Prespecified Diet Plan

Figure 6 shows the forest plot of the meta-analysis examining the effect of health coaching on diet adherence stratified by inactive and active comparator subgroups. The pooled estimate for 5 studies indicated a nonsignificant effect for health coaching interventions on diet adherence when compared with an inactive comparator (SMD 0.05; 95% CI -0.08 to 0.19). This summary estimate did not exhibit heterogeneity (I^2^=0%). Of the 5 studies using inactive comparators, 1 was rated as low ROB^16^ 2 as unclear ROB,^21,45^ and 2 as high ROB.^20,58^

Figure 6 Effect of Health Coaching on Adherence to a Prespecified Diet Plan

Abbreviations: CI=confidence interval; SD=standard deviation

In the one active comparison study in adults with type 2 diabetes,^30^ participants were randomized to one of 3 groups: web-based information alone, or web-based information with either peer support or tailored self-management from a coach. There were no significant differences between those who received peer support compared with those who did not. There was a small positive effect (SMD 0.26; 95% CI -0.08 to 0.60) that was not statistically significant for health coaching in the form of tailored self-management when compared with an active comparator that did not include health coaching in the form of tailored self-management.

##### Change in Dietary Fat Consumption

Figure 7 shows the forest plot of the meta-analysis examining the effect of health coaching on change in dietary fat intake stratified by inactive and active comparator subgroups. The pooled estimate indicated a small statistically significant pooled effect for health coaching to decrease dietary fat intake when compared to an inactive comparator (SMD -0.21; 95% CI -0.31 to -0.10). This summary estimate had low heterogeneity (I^2^=4%). There was also a small pooled effect (SMD -0.22; 95% CI -0.41 to -0.03) that was statistically significant for health coaching to reduce dietary fat intake when compared with an active comparator. This summary estimate also had low heterogeneity (I^2^=0%).

Figure 7 Effect of Health Coaching on Fat Consumption

Abbreviations: CI=confidence interval; SD=standard deviation; SMD=standardized mean difference

Two of the studies using active comparators had more than 2 arms.^29,30^ As stated for diet adherence, one study^30^ also examined the effect of peer support but did not find any effect on grams of daily fat intake. In the other,^29^ coaching was delivered by phone as well as in a group setting compared with the intensive weight control program currently offered by the VA (MOVE!). The figure shows that group coaching decreased fat intake more than MOVE!. Phone coaching also decreased fat intake more than MOVE! at 12 months (MD -1.6gm vs -0.8gm), but this difference was not statistically significant between groups. The difference between the 2 types of coaching, phone (-1.6gm fat) and group (-2.3gm fat), also was not statistically significant. Both of these studies had relatively large sample sizes (n>300) and were rated as high ROB.

##### Change in Total Calories

Only 2 studies measured total energy or kilocalorie intake; we summarize them qualitatively.^16,19^ The study rated as high ROB^19^ had 45 participants with obesity and compared phone coaching with a certified health coach to a scripted phone education lesson based on the LEARN manual, both provided once/week for 12 weeks. Diet was measured via a 24-hour recall that was reviewed with a staff member at 5 time points: baseline, 6 weeks, 12 weeks (end of treatment) and 3 and 6 months post-treatment. There was a significant difference (p<.05, r=0.32) between groups at 12 weeks (coaching mean: -626.8kcal, SE=167.4 vs LEARN mean: -105.5kcal, SE=180.3). Both groups maintained reduced caloric intake at 3 and 6 months post-treatment, but differences between groups were no longer significant. The study rated as low ROB^16^ had a 2×2 factorial design study with 574 hypertensive participants and assessed the separate and combined influences of a physician training intervention and a patient intervention with lifestyle coaching over 6 months. Both groups that contained coaching elements decreased daily caloric intake more than the groups that did not contain coaching at both 6 (250-287kcal vs 72-171kcal, p<0.05) and 18 months (159-261kcal vs 73-119kcal), but was no longer significant at 18 months. Both of these studies indicate that coaching has a positive effect on total calorie reduction.

##### Change in Fruit and Vegetable Consumption

Five studies examined the outcome of fruit and vegetable consumption: 3 used an inactive comparator^16,20,31^ and 2 used an active comparator.^19,29^ However, measurement varied considerably between studies and meta-analysis could not be performed. We summarize these qualitatively.

The 3 studies with inactive comparators were all moderately large (n=270 to 574) but varied on population, how fruit and vegetable consumption was measured, and quality. A study rated as unclear ROB^31^ examined 410 colorectal cancer patients using a cancer-specific food frequency questionnaire that asked about fruit and vegetable intake separately. There were no significant differences at 6 or 12 months in fruit intake between the phone coaching intervention and usual care. However, at 6 months patients in the coaching group ate 0.4 more servings of vegetables per day (p=0.001) than usual care. This difference was not maintained at 12 months.

A study rated as high ROB^20^ examined 270 patients with diabetes who were either Hispanic or African American. The study compared culturally tailored self-care coaching delivered by medical assistants over 6 months to enhanced treatment as usual. They used the 5-item diet subscale of the Summary of Diabetes Self-care Activities, which does not isolate fruit and/or vegetable consumption. There were no significant differences between groups at either time point. The last study, rated as low ROB,^16^ examined 574 patients with hypertension in a nested 2×2 design over 18 months: physician intervention (MD-I) or control (MD-C) and patient intervention (PT-I) (which included lifestyle coaching) or control (PT-C). Intake was measured by the Block Food Frequency Questionnaire. At 6 months, both MD-I and PT-I showed significant increased fruit and fruit juice consumption over control groups (p<0.05 and p<0.001, respectively). A significant difference was maintained at 18 months in the PT-I group but not the MD-I group.

The 2 studies with active comparators were both rated as high ROB.^19,29^ The first was a 3-arm study^29^ that used a food frequency questionnaire to measure diet. It is described under fat intake. The other study^19^ used 24-hour recalls to measure diet. It is described under calorie intake (above). Neither study found any difference between groups in fruit and vegetable consumption.

#### Effects on Smoking

Two of the eligible RCTs examined the impact of health coaching on smoking behavior.^31,53^ Neither trial found an effect of health coaching on smoking behavior. However, neither trial was designed to address smoking behavior solely, targeting multiple health behaviors. One trial (n=792) rated as low ROB investigated a phone-based coaching program compared to usual care in individuals with coronary heart disease.^53^ Participants received five 20- to 30-minute coaching calls delivered by a nurse or dietician over the course of 6 months. At 6 months, there was no difference between groups in self-reported rates of smoking cessation.

The other trial rated as unclear ROB investigated the effect of health coaching on multiple health behaviors among 410 individuals with colorectal cancer.^31^ This study compared an 11-session, 5-week phone-based coaching program with enhanced usual care. Sessions were delivered by nurses, behavioral specialists, or health educators and lasted an average of 31.5 minutes. Individuals in this trial reported a low rate of current smoking at baseline (3.9% in health coaching vs 4.3% in usual care), limiting the trial's ability to detect changes in smoking behavior over time. There were no differences between groups in self-reported current smoking at 6 months (the predetermined secondary outcome time point; 2.0% in health coaching vs 4.2% in usual care); or at a 12-month follow-up (1.0% in health coaching vs 5.3% in usual care).

#### Effects on Medication Adherence

Three of the eligible RCTs examined the impact of health coaching on medication adherence outcomes in patients with diabetes.^21,59,61^ All 3 studies were rated as unclear ROB and used weak controls consisting of usual care. One study^59^ found that health coaching was associated with a significant improvement in medication adherence, but 2 studies^21,61^ did not find a positive effect on medication adherence.

The first study compared an in-person individual health coaching intervention with usual care.^59^ This study evaluated medication adherence based on patient self-report in which the mean number of days of adherence across all medications was calculated. Health coaching had a positive effect on medication adherence with participants in the intervention group reported 1.08 more days of medication adherence compared to usual care (p<0.001). The second study evaluated a phone-based coaching intervention compared with a standard educational brochure.^21^ This study operationalized medication adherence as the number of the past seven days the patient took all of prescription medications prescribed by his or her doctor. While participants in the health coaching group reported improved medication adherence, these results were not statistically significantly different from the control condition. The third study compared a motivational interviewing and mindfulness-based phone intervention with usual care.^61^ There was a significant reduction in barriers to medication adherence, as measured by the Morisky Adherence Scale, within the health coaching group (Z -2.862; p=0.004), but there was no significant time-by-group interaction.

### Detailed Findings for Self-efficacy (KQ 1c)

Eight of the eligible RCTs examined the impact of health coaching interventions on self-efficacy outcomes for these chronic disease conditions: type 2 diabetes (n=6), obesity (n=1), and arthritis (n=1).^22,24,34,35,45,54,62,63^ Table 10 summarizes key elements of the 8 studies.

Table 10 Evidence Profile of Studies Reporting Change in Self-efficacy

Number of trials: 8 published 2009-2015. Number of participants: 1469 total (average/trial=184, range 22 to 473). Setting: Most participants were recruited from primary care (n=4) or community clinics (n=4); 1 study recruited from a specialty rheumatology clinic. Countries: 3 countries were represented (Australia, the Netherlands, USA; 62.5% were conducted in the USA). Key elements of health coaching: Patient-centeredness and self-discovery process were equally prominent (75% of studies), and patient-determined goals were reported in 87.5% of studies. Comparisons: 1 study had an active comparator (an equal number of individual meetings with a fitness specialist); the other 7 trials used usual care, treatment as usual, waitlist, or education. Measurement of outcomes: Self-efficacy was reported using 7 different questionnaires within the 8 trials: 2 used the Diabetes Empowerment Scale; other scales were Stanford Chronic Disease Self-efficacy, Bandura Self-efficacy, Diabetes Self-efficacy, Diabetes Management Self-efficacy, Exercise Self-efficacy scales, and the Multidimensional Diabetes Questionnaire (self-efficacy subscale). Risk of bias: 1 study was rated as low ROB, 5 as unclear ROB, and 2 as high ROB.

All 8 studies examined the impact of health coaching on self-efficacy using questionnaires with continuous scales and were therefore amenable for quantitative synthesis. However, there was substantial variability in the questionnaires used to measure self-efficacy, so all summary estimates were calculated as SMDs. We stratified results by comparator type (inactive vs active) and present stratified and overall pooled estimates when feasible.

The 8 trials used in the self-efficacy meta-analysis comprised 7 inactive comparators^24,34,35,40,45,54,62^ and one active comparator.^22^ Figure 8 shows the forest plot examining the effect of health coaching on self-efficacy stratified by inactive and active comparator subgroups. The 7 trials with inactive comparators contained 1,196 participants and were rated as unclear ROB (n=5), high ROB (n=1), or low (n=1) ROB. When compared with inactive controls (usual care, n=5; waitlist, n=1; education only, n=1), the pooled estimate demonstrated a small-to-moderate positive effect of health coaching interventions on self-efficacy that was statistically significant (SMD 0.41; 95% CI 0.21 to 0.62) with moderate heterogeneity (I^2^=52.2%).

Figure 8 Effect of Health Coaching on Self-efficacy

Abbreviations: CI=confidence interval; SD=standard deviation

The study with an active comparator^22^ had 137 participants and was rated as high ROB. This study compared 2 contact-equivalent conditions of 6 monthly, 1-hour individual meetings with a YMCA “Coach Approach-trained” wellness specialist compared to 6 sessions with a standard trained fitness specialist. This study demonstrated a moderate positive effect of health coaching on self-efficacy that was statistically significant (SMD 0.58; 95% CI 0.27 to 0.89).

### Quality of Evidence for KQ 1

#### Risk of Bias

Figure 9 presents a summary of the evaluation of the ROB, which shows a graph with review authors' judgments about each ROB item presented as percentages across all included studies. The white sections of the bars indicate the trials that did not measure a specific outcome. Appendix C describes the quality assessment criteria and presents a table of quality assessment responses for the 41 studies.

Figure 9 Risk of Bias Graph^a^ a For the overall score, low ROB required random sequencing, allocation concealment, and blinding in order to be scored low risk with no other important concerns; unclear ROB was assigned if 1 or 2 domains were scored not clear or not done; high ROB was assigned if >2 domains were scored not clear or not done.

#### Selection Bias

##### Random Sequence Generation

Almost all included studies (95%) described treatment allocation as random. However, 13 (33%) of these 39 studies did not give the methods used to generate the random sequence and were thus judged as unclear ROB. Two studies were judged as high ROB because they did not address randomization at all.

##### Allocation Concealment

In 20 of the 41 trials (49%), methods for allocation concealment were described in sufficient detail to determine whether the intervention allocation could have been foreseen in advance of or during enrollment, resulting in a judgment of low ROB. In many trials (18 of 41 [44%]), there was an unclear ROB due to inadequate detail about allocation concealment provided by authors. The remaining 3 trials^26,34,48^ (7%) were judged as high ROB because they either stated a procedure that could have caused allocation to become unblinded or they did not state whether the trial was randomized at all.

#### Performance Bias

For the outcome of clinical indicators (eg, A1c or blood pressure), which was measured in 33 (80%) studies, risk of bias was low in most studies (73%) as a result of adequate reporting of blinding or incomplete blinding that review authors judged was not likely to be a significant source of bias. In 6 of 33 trials (18%), there was an unclear ROB due to inadequate information regarding blinding. Three (9%) studies were judged as high ROB due to lack of blinding.

For the outcome of physical activity, which was measured in 17 (41%) studies, the blinding of participants and personnel was highly variable. Of the 17 trials measuring physical activity as an outcome, none were judged as low ROB. Eight trials (47%) were judged as unclear ROB due to inadequate information regarding blinding. Nine studies were judged as high ROB due to lack of blinding or incomplete blinding that review authors judged to be a potential source of bias.

Similar to physical activity, for diet outcomes, which were measured in 10 (24%) studies, the blinding of participants and personnel was highly variable. Of the 10 trials measuring diet as an outcome, only 2 (20%) were judged as low ROB as a result of adequate reporting of blinding. In 5 trials (50%), there was unclear ROB due to inadequate information regarding blinding. Three studies (30%) were judged as high ROB due to lack of blinding or incomplete blinding that review authors judged to be a potential source of bias.

The 3 other outcomes were measured in fewer than 10 studies. For self-efficacy (n=8, 19.5%), only one of the 8 studies (12.5%) was judged as low ROB as a result of adequate reporting of blinding. Four studies (50%) were judged as unclear ROB due to inadequate reporting, and 3 studies (37.5%) were judged as high ROB due to lack of blinding. For medication adherence (n=3, 7%), none were judged as low ROB. One was judged as unclear ROB due to inadequate information and the other 2 were judged as high ROB due to lack of blinding. Only 2 studies (5%) examined the outcome of smoking. One was judged as low ROB and the other was judged as unclear ROB.

#### Detection Bias

For the outcomes that were clinical variables (eg, HbA1c, BMI, blood pressure), measured in 33 of the 41 trials (80.5%), there was sufficient information provided by the authors regarding blinding of the outcome assessment in 25 of the 33 trials (76%) to be judged as low ROB. In the remaining 8 trials, 7 (21%) gave insufficient information regarding outcome blinding assessment, resulting in a judgment of unclear ROB, while 1 (3%) gave no information in regard to blinding and so was judged as high ROB.

For the outcomes that were health behaviors (ie, physical activity, diet, smoking, and medication adherence), measured in 22 of the 41 trials, 7 (32%) gave sufficient information provided by the study authors about blinding of outcome assessments to be judged as low ROB. Nine trials (41%) gave insufficient information regarding outcome blinding assessment and thus were judged as unclear ROB. Six trials (27%) were judged as high ROB due to lack of blinding.

Self-efficacy was measured in 8 trials, of which 3 (37.5%) gave sufficient information from the authors about blinding of the outcome assessment to be judged as low ROB. Four trials (50%) provided inadequate information about outcome blinding and so were judged as unclear ROB. One trial was judged as high ROB due to lack of blinding.

#### Attrition Bias

All trials reported the numbers randomized to each group. Approximately half the trials (20 of 41 [49%]) reported complete outcome data that included information on attrition, reasons for attrition or exclusion, and how missing data was handled in the analysis. The other 21 trials were judged as unclear ROB (n=10, 24%) or high ROB (n=11, 27%) because the dropout rate was too high, they did not disclose the reason for attrition/exclusion in sufficient detail, or they did not account for missing data in the analysis.

#### Reporting Bias

The majority of trials (32 of 41 [76%]) reported details of the measured outcomes sufficient to be judged as low ROB. Seven trials (17%) did not give sufficient information on the outcomes and were therefore judged as unclear ROB. Two trials (5%) did not report at all on at least one of the outcomes proposed in the methods and were therefore judged as high ROB for selective outcome reporting.

#### Other Bias

The majority of trials (35 of 41 [85%]) provided sufficient details not to raise concerns about bias of a nature not covered within the other domains mentioned. Four trials did not provide sufficient methodological detail and were thus judged as unclear ROB, whereas 2 trials (5%) were judged as high ROB stemming from between-group imbalances present at baseline even though randomized and not controlled in the analysis.

#### Overall Risk of Bias

Overall ROB was assessed for each included study (Figure 10). Almost half the studies (20 of 41 [49%]) were judged as unclear ROB, 15 (36.5%) as high ROB, and only 6 (14.5%) as low ROB.

Figure 10 Risk of Bias Summary: Review Authors' Judgments About Risk of Bias Items for Each Included Study^a^

## KEY QUESTION 2 Among adults, does the impact of health coaching vary by a. Characteristics of the population (eg, type of chronic medical illnesses) b. Dose of the intervention (eg, number and frequency of sessions, minutes of contact) c. Mode of delivery (eg, individual visits vs group visits, face-to-face vs telephone) d. Types of individuals conducting coaching interventions (eg, peers, nurses, health educators, health coaches) e. Concordance with key elements of health coaching (ie, patient-centeredness, patient identification of goals, self-discovery process)

### Key Points

- We explored the variable impact of health coaching by multiple single factors that may contribute to heterogeneity (ie, recruited populations, intervention dose, mode of intervention delivery, coach type, concordance with key elements of health coaching). None of these individual factors was a robust predictor of heterogeneity. Yet some qualitative patterns of effects emerged.
  ○ Regardless of moderator category, most subgroups produced effects that were in the same direction but varied in magnitude, generally ranging from small to medium effect sizes in subgroups.
  ○ While results on dose of intervention are inconclusive, there is some evidence that doses that were in the middle of the range in number of planned sessions may yield more benefit than those with smaller or larger numbers of planned sessions.
  ○ Health coaching delivered either by telephone or in person yielded similar small to moderate positive effects across several outcomes. However, not all estimates were statistically significant.
  ○ The majority of analyses identified no clear pattern of effect by type of individual conducting the coaching intervention. There is some limited evidence from studies that reported HbA1c and physical activity outcomes that use of behavioral healthcare providers may positively influence the effect of health coaching; however, this evidence is limited and inconsistent.
  ○ The intervention concordance score, a variable designed for this report to attempt to identify important elements of health coaching, does not appear to have any consistent effect.

For KQ 2, we present detailed findings exploring the variability of effects of health coaching by the 5 key moderators of interest. Studies that were amenable to meta-analysis were assessed to see if changes in outcomes varied by population characteristics (KQ 2a), intervention dose (ie, number of planned sessions of health coaching) (KQ 2b), mode of coaching delivery (KQ 2c), type of individual providing the coaching (eg, healthcare provider, peer) (KQ 2d), and intervention concordance score (KQ 2e). When we had 3 or more studies in a category, we performed a meta-analysis. We use forest plots to visually inspect the data for patterns and synthesize findings qualitatively.

In keeping with the structure of KQ 1, we organize the findings in KQ 2 by the 3 types of outcomes—clinical health outcomes, patient health behaviors, and self-efficacy—and within those, we describe variations by the 5 key moderators of interest.

### Detailed Findings for Clinical Health Outcomes

In this section, we describe findings by effects on HbA1c, cardiovascular health (systolic blood pressure, cholesterol), and functional status.

#### Effects on HbA1c

Twenty of the eligible RCTs examined the impact of health coaching on HbA1c.^20,21,24,27,28,30,33,34,39-41,44-46,49,55,57-59,61^ Of these, 19 were amenable to meta-analysis and were examined for heterogeneity of effects by the key moderators of interest.

##### Variation by Population Characteristics

Of the 20 trials, we had sufficient studies to pool effects for one population subgroup: those with diabetes. This subgroup had 17 studies. The other group comprised studies that recruited populations with a variety of chronic medical conditions and only contained 2 studies. Both subgroups displayed a similar direction of effect but the magnitude of the effect was different (Figure 11). Those recruited for diabetes had a smaller effect size (-0.21; 95% CI -0.40 to -0.02) compared to the rage of effect sizes for the studies comprised of mixed populations (range -0.90 to -0.80).

Figure 11 Effect of Health Coaching on A1c by Population Characteristics

##### Variation by Dose

Eighteen studies had enough information to determine the dose of the intervention measured as planned number of intervention contacts. The number of planned contacts ranged from 5 to 156, with a median of 15. Qualitatively, we did not see any evidence of a dose response number of session on the outcome of HbA1c (Figure 12).

Figure 12 Effect of Health Coaching on A1c by Dose (Number of Planned Contacts)

##### Variation by Mode

Studies generally delivered their coaching intervention by phone (n=11),^20,21,24,33,34,44-46,55,57,61^ in person (n=4),^39,40,58,59^ or with some mix of those 2 (n=3).^27,28,49,52^ One study used a web-based coaching intervention.^30^ Subgroups displayed a similar direction of effect, but the magnitude of the effect was slightly different. Studies that used a mix of phone and in-person sessions had a slightly greater impact, but all pooled subgroup effects were not statistically significant (Figure 13).

Figure 13 Effect of Health Coaching on A1c by Mode of Delivery

##### Variation by Types of Individuals Conducting Coaching Interventions

Studies used a wide variety of personnel in the health coaching role (Figure 14). Nine used a nurse or other licensed healthcare provider^20,21,24,27,39,44,55,58,59^ as the coach. Four used a licensed behavioral provider, typically a psychologist or social worker.^28,45,57,61^ Two used peer coaching,^46,49^ and 4 used some other personnel as coaches (nurse or lay health worker at study discretion^34^; unspecified employees of the healthcare system^33^; professional life coaches^40^; masters'-level health science students^30^). Qualitatively, most coach types appeared roughly equally effective, with behavioral health providers having the largest pooled effects.

Figure 14 Effect of Health Coaching on A1c by Type of Coach

##### Variation by Concordance

An equal number of studies received concordance scores of 3 or the maximum, 4 (Figure 15). No clear pattern emerged when we conducted exploratory subgroup analysis by concordance score; however, only the summary estimate for a concordance score of 4 was statistically significant and was similar in magnitude for the pooled estimate for the impact of health coaching compared to an inactive comparator in KQ 1 (-0.36 vs -0.30).

Figure 15 Effect of Health Coaching on A1c by Concordance

#### Effects on Cardiovascular Health

Six of the eligible RCTs examined the impact of health coaching on one or more cardiovascular outcomes across the chronic disease conditions.^16,41,51-53,59^ Results are grouped by key moderators of interest and then by the 2 prioritized outcomes of systolic blood pressure and cholesterol. Due to variability in reported outcomes, findings are synthesized qualitatively.

##### Variation by Population Characteristics

[underlined: Systolic blood pressure]. Five studies reported the impact of health coaching on systolic blood pressure across the following conditions: cardiovascular disease,^53^ hypertension,^16,51^ coronary artery disease or congestive heart failure,^41^ or a mixture of conditions.^59^ Only the 2 studies that examined the effects of health coaching on cardiovascular outcomes in patients with hypertension found a positive impact on this outcome.^16,51^ The other 3 studies in the following populations found no significant effect of health coaching on systolic blood pressure outcomes: cardiovascular disease,^53^ coronary artery disease or congestive heart failure,^41^ and mixed population (patients with one or more of uncontrolled diabetes, hypertension, or hyperlipidemia).^59^

[underlined: Cholesterol]. Four of the 6 studies examined the impact of health coaching on change in cholesterol across these conditions: cardiovascular disease,^52,53^ coronary artery disease or congestive heart failure,^41^ and mixed population.^59^ Results were mixed. Both studies conducted in populations with cardiovascular disease demonstrated positive results only on changes in cholesterol,^27,52,53^ while the other 2 studies conducted in mixed populations did not yield statistically significant findings.^41,59^ Table 11 summarizes the finding for both systolic blood pressure and cholesterol.

Table 11 Impact of Health Coaching on Key Cardiovascular Outcomes by Population

Population | Systolic Blood Pressure (n=5) | | Cholesterol (n=4)
Population | Positive Effect Studies | No Effect Studies | Positive Effect Studies | No Effect Studies
Hypertension | 2 | 0 | 0 | 0
Cardiovascular disease | 0 | 1 | 2 | 0
Coronary artery disease/congestive heart failure | 0 | 1 | 0 | 1
Mixed population | 0 | 1 | 0 | 1

##### Variation by Dose

[underlined: Systolic blood pressure]. Of the 5 studies that reported systolic blood pressure outcomes, 3 studies had 10 or more planned contacts (range 11 to 20)^16,41,59^ and 2 had fewer than 10 contacts (range 5 to 6).^36,51,53^ Results were mixed; only one of the 3 interventions with 10 or more contacts had positive findings.^16^ Similarly, only one of the 2 interventions with fewer than 10 contacts had a positive impact on systolic blood pressure.^51^

[underlined: Cholesterol]. Of the 4 studies that reported cholesterol outcomes, 2 had 10 or more planned contacts,^41,59^ and 2 had fewer than 10 planned contacts.^52,53,55^ No clear pattern emerged; both studies that had more contacts did not product a significant impact on cholesterol, while the group with the smaller dose produced one study with statistically significant findings.^53^ Table 12 summarizes the finding for both systolic blood pressure and cholesterol.

Table 12 Impact of Health Coaching on Key Cardiovascular Outcomes by Intervention Dose

Number of planned contacts | Systolic Blood Pressure (n=5) | | Cholesterol (n=4)
Number of planned contacts | Positive Effect Studies | No Effect Studies | Positive Effect Studies | No Effect Studies
Fewer than 10 planned contacts | 1 | 1 | 1 | 1
10 or more planned contacts | 1 | 2 | 0 | 2

##### Variation by Mode

[underlined: Systolic blood pressure]. Of the 5 trials that assessed systolic blood pressure, 2 studies used primarily in-person health coaching,^16,59^ and 3 studies used primarily phone-based coaching.^41,51,53^ Across both modes of delivery, results were mixed. Only one phone-delivered study^51^ and one in-person study^16^ produced significant impacts on systolic blood pressure.

[underlined: Cholesterol]. Of the 4 trials that assessed changes in cholesterol, only one study used primarily in-person health coaching,^59^ and 3 studies used primarily phone-based coaching.^41,52,53^ Again, results were mixed. Only 2 phone-based studies produced significant effects.^52,53^ Table 13 summarizes the finding for both systolic blood pressure and cholesterol.

Table 13 Impact of Health Coaching on Key Cardiovascular Outcomes by Intervention Delivery Mode

Mode of Delivery | Systolic Blood Pressure (n=5) | | Cholesterol (n=4)
Mode of Delivery | Positive Effect Studies | No Effect Studies | Positive Effect Studies | No Effect Studies
In-person health coaching | 1 | 1 | 0 | 1
Phone-based health coaching | 1 | 2 | 2 | 1

##### Variation by Type of Coach

[underlined: Systolic blood pressure]. Of the 5 trials that assessed systolic blood pressure, 3 studies used healthcare providers (ie, nurse or medical assistant) to deliver the coaching intervention.^41,53,59^ One study used a peer coach,^51^ and another used a trained health educator.^16^ There was a consistent pattern of effects. The 3 interventions delivered by a healthcare provider did not have significant effects on systolic blood pressure, while the 2 interventions delivered by a non-healthcare provider did report significant effects of health coaching on systolic blood pressure.

[underlined: Cholesterol]. All 4 studies that reported cholesterol outcomes used some form of a healthcare provider, including nurse,^41,53^ dietician,^52^ or medical assistant,^59^ to deliver the coaching intervention. No clear pattern emerged from the data. Only one of the 2 nurse-led interventions reported a positive impact on cholesterol.^53^ The other study with a positive outcome was delivered by a dietician.^52^ Table 14 summarizes the finding for both systolic blood pressure and cholesterol.

Table 14 Impact of Health Coaching on Key Cardiovascular Outcomes by Type of Individual Conducting Coaching Intervention

Coach Type | Systolic Blood Pressure (n=5) | | Cholesterol (n=4)
Coach Type | Positive Effect Studies | No Effect Studies | Positive Effect Studies | No Effect Studies
Healthcare provider | 0 | 3 | 2 | 2
Peer coach and/or trained health educator | 2 | 0 | 0 | 0

##### Variation by Concordance

[underlined: Systolic blood pressure]. The 5 studies of health coaching that reported impacts on systolic blood press had the following range of concordance scores: one study each for a score of 1,^41^ 2,^16^ or 3,^51^ and 2 studies with a score of 4.^53,59^ No clear pattern emerged. Of the trials reporting no statistically significant effects, one had a concordance score of 1,^41^ and 2 had the highest possible concordance score of 4.^53,59^ The 2 positive studies had concordance scores of 2^16^ and 3.^51^

[underlined: Cholesterol]. The 4 studies of health coaching that reported impacts on cholesterol had the following concordance scores: one study with a scores of 1^41^ and 3 studies with a score of 4.^49,52,53,59^ Similar to systolic blood pressure, no clear pattern of effects emerged by concordance score. While both positive impact studies had scores of 4, a no impact study also had a score of 4.^59^ The only consistent finding was that, across both outcomes, the study with the concordance score of 1 did not have a statistically significant impact on either of the prioritized cardiovascular outcomes. Table 15 summarizes the finding for both systolic blood pressure and cholesterol.

Table 15 Impact of Health Coaching on Key Cardiovascular Outcomes by Concordance Score

Concordance Score | Systolic Blood Pressure (n=5) | | Cholesterol (n=4)
Concordance Score | Positive Effect Studies | No Effect Studies | Positive Effect Studies | No Effect Studies
1 | 0 | 1 | 0 | 1
2 | 1 | 0 | 0 | 0
3 | 1 | 0 | 0 | 0
4 | 0 | 2 | 2 | 1

#### Effects on Functional Status

Two of the eligible RCTs examined the impact of health coaching interventions on functional status compared with inactive controls.^35,47^ Functional status was examined as both a self-reported outcome in one study^35^ and as an objective 6-minute walk test in another.^47^ Results are grouped by key moderators of interest and summarized qualitatively.

##### Variation by Population Characteristics

Both coaching interventions that reported effects on functional status sought to increase physical activity in individuals with physically disabling conditions or rheumatoid arthritis^35^ and multiple sclerosis.^47^ Results were mixed. The study of patients with multiple sclerosis found a positive effect of health coaching on functional status.^47^ However, the study of patients with rheumatoid arthritis demonstrated no positive effect of health coaching on functional status, as indicated by self-reported disability scores.^35^

##### Variation by Dose of Intervention

One study had fewer than 10 planned contacts^35^ and one study had 10 or more planned contacts.^47^ The latter study, with 15 planned contacts,^47^ found a positive effect of health coaching on functional status, while the other study did not.^35^

##### Variation by Mode of Delivery

One study delivered the health coaching intervention via video chat using Skype and found a positive effect of health coaching on functional status.^47^ The second study delivered the health coaching intervention using a mix of in-person group sessions and individual phone calls but did not find a positive effect of health coaching on functional status.^35^

##### Variation by Type of Individual Conducting Coaching Intervention

One study did not report on the type of personnel used as a coach.^47^ The second study used healthcare providers to deliver the health coaching intervention.^35^ No positive effects on functional status were found.

##### Variation by Concordance

Both studies demonstrated low concordance with key health coaching elements, with scores of 1^47^ and 2.^35^ The study with lower concordance was the only study to find a positive effect of health coaching on functional status.^47^

### Detailed Findings for Patient Health Behaviors

In this section, we describe findings by effects of health coaching on physical activity, weight management, smoking, and medication adherence.

#### Effects on Physical Activity

Seventeen of the eligible RCTs examined the impact of health coaching on physical activity.^20,21,25,26,29-32,35,43,45,47,48,54,55,58,61^ We organize the findings based on the subgroups for the outcome physical activity as follows: (1) physical activity change (a continuous variable representing steps or minutes of exercise) and (2) physical activity threshold (a continuous variable representing achievement of some threshold of exercise). The 15 studies that were amenable to meta-analysis were assessed to see if effects on physical activity varied by the key moderators.

##### Variation by Population Characteristics

[underlined: Physical activity change.] Change was reported in the following medical conditions: diabetes^30,55,58^ (n=3), obesity^29,61^ (n=2), multiple sclerosis^47^ (n=1), breast cancer^43^ (n=1), colorectal cancer^31^ (n=1), arthritis^35^ (n=1), and mixed conditions^32^ (n=1). Figure 16 shows the forest plot organized by medical condition. Studies showed that same trend of a positive impact of health coaching on physical activity change; however, across the 7 populations, there were major differences in effect sizes (SMD range 0.02 to 0.63). No clear pattern of effects by population emerged; subgroups with more than one study produced a mix of significant and not significant results.

Figure 16 Effect of Health Coaching on Physical Activity Change by Population Characteristics

[underlined: Physical activity threshold.] Threshold was reported in 5 studies^20,21,45,54,61^; all 5 were conducted among populations with diabetes. Thus we were not able to explore the differential impact of health coaching by population on physical activity threshold (Figure 17).

Figure 17 Effect of Health Coaching on Physical Activity Threshold by Population Characteristics

Two additional trials assessed physical activity threshold through categorical variables and therefore could not be combined with the studies above. Neither study found statistically significant impacts of health coaching on threshold. In brief, one study^25^ examined the effects of health coaching on physical activity in adult females with systemic lupus erythematosus and found no statistically significant differences between the intervention and inactive control groups. A second study^26^ assessed the effects of health coaching on physical activity in patients with rheumatoid arthritis. Although the intervention group increased the number of patients who attained the physical activity “health goal,” the increase was not significantly different from the increase in the control group.

##### Variation by Dose

[underlined: Physical activity change]. Change was reported in 10 studies^29-32,35,43,47,48,55,58^ whose “intervention dose” ranged from 5 to 80 planned sessions of health coaching. Figure 18 shows the forest plot organized by number of sessions. The SMD range was -0.05 to 0.63. With one exception (SMD -0.03; 95% -0.50 to 0.43),^55^ all studies with 20 or fewer planned sessions showed a small positive effect of intervention dose on health coaching (all SMD ≥0.20). Three of these results,^32,43,47^ with intervention doses of 6, 12, or 15 sessions, were significant. Conversely, 2 studies with the highest numbers of planned sessions, 28 and 80, found negligible effect sizes (SMD-0.05 and 0.02) that were not significant.

Figure 18 Effect of Health Coaching on Physical Activity Change by Intervention Dose

[underlined: Physical activity threshold.] Threshold was reported in 5 studies^20,21,45,54,61^ whose intervention dose ranged from 3 to 18 planned sessions. Figure 19 shows the forest plot organized by number of sessions. Two studies^21,54^ had fewer than 6 planned sessions and exhibited negative effects (SMDs -0.16 and -0.21) that were not significant. The other three studies^20,45,61^ had 14 to 18 planned sessions and exhibited positive effects (SMDs 0.12 to 1.50), 2 of which were significant.^45,61^

Figure 19 Effect of Health Coaching on Physical Activity Threshold by Intervention Dose

The 2 trials that assessed physical activity threshold through categorical variables have been described previously. Both had an average of 12 planned sessions. In brief, one study^25^ provided individual coaching every 6 weeks for 3 months decreasing over a year. The other study^26^ provided monthly coaching sessions. Neither found a statistically significant difference between the intervention and control groups on physical activity.

##### Variation by Mode

[underlined: Physical activity change]. Change was reported in 10 studies^29-32,35,43,47,48,55,58^ wherein mode of delivery was sorted into 5 categories: telephone^31,43,48,55^ (n=4), in-person^29,32,58^ (n=3), web^30^ (n=1), video^47^ (n=1), and mixed^35^ (n=1). Figure 20 shows the forest plot organized by type of delivery mode. Across the delivery modes, there were differences in effect sizes (SMD range -0.05 to 0.54). Meta-analysis was possible for 2 types of delivery mode, telephone and in-person; both subgroups displayed a similar magnitude of effects, but neither pooled estimate was significant. The other 3 modes examined had only one eligible trial each. One of these studies, one showed a moderate positive effect of health coaching via video that was significant.^47^ The other 2 studies, which used the web^30^ and “mixed” mode of delivery,^35^ found negligible to small effect sizes that were not significant.

Figure 20 Effect of Health Coaching on Physical Activity Change by Mode of Delivery

[underlined: Physical activity threshold.] Threshold was reported in 5 studies,^20,21,45,54,61^ all with inactive comparators, 4 of which used the telephone as the mode of delivery^20,21,45,61^ while one used in-person as the mode of delivery.^54^ The 2 types of delivery modes produced effects that were different in magnitude and direction. The pooled estimate for the 4 telephone-delivered studies produced a small, positive effect that was not statistically significant. The one study that used in-person health coaching as the mode of delivery found a small negative effect for in-person coaching that was not significant (Figure 21).

Figure 21 Effect of Health Coaching on Physical Activity Threshold by Mode of Delivery

The 2 trials that assessed physical activity threshold through categorical variables have been described previously. One study^26^ provided in-person coaching sessions, while the other study^25^ provided coaching via phone. Neither study found a statistically significant difference between the intervention and inactive control groups on physical activity, which is congruent with the findings reported above.

##### Variation by Type of Individual Conducting Coaching Intervention

[underlined: Physical activity change]. Change was reported in 10 studies that used the following types of individuals as coaches: healthcare provider^32,35,55,58^ (n=4), “other”^29,30,48^ (n=3), behavioral health provider^31^ (n=1), peer coach^43^ (n=1), and “not reported”^47^ (n=1). Figure 22 shows the forest plot organized by type of coach. Across the coach types, effect sizes were consistently positive although varying in magnitude and statistical significance (SMD range: 0.03 to 0.63). There were 2 categories of coach type, healthcare provider and “other,” for which there were enough studies to perform a meta-analysis. The meta-analysis for healthcare provider (n=4) found a significant positive effect for health coaching on physical activity (SMD 0.30; 95% CI 0.09 to 0.52) with negligible heterogeneity (I^2^=0.0%). The meta-analysis for “other” provider type found a negligible effect of health coaching on physical activity (SMD 0.03; 95% CI -0.31 to 0.36) that was not significant.

Figure 22 Effect of Health Coaching on Physical Activity Change by Type of Coach

There was one study each for peer coaches,^43^ behavioral health providers,^31^ and unidentified type of coach.^47^ All found a small to a moderate positive effect of health coaching (SMD range 0.20 to 0.63), but only the peer coach study and the unidentified type of coach study produced moderate effect sizes that were statistically significant. The third study found a small, positive effect that was not significant for behavioral health providers.

[underlined: Physical activity threshold.] Threshold was reported in 5 studies^20,21,45,54,61^; 2^20,21^ used healthcare providers, 2^45,61^ used behavioral health providers, and one^54^ used peer coaches. Results are converse to those found for physical activity change above. The 2 studies that used healthcare providers^20,21^ both found negligible effects (SMD range -0.16 to 0.12) that were not significant. The 2 studies that used behavioral health providers^45,61^ both found sizeable positive effects that were significant (SMD range 0.62 to 1.50). The study using peer coaches found a negative effect that was not significant (SMD -0.21) (Figure 23).

Figure 23 Effect of Health Coaching on Physical Activity Threshold by Type of Coach

Two trials assessed physical activity threshold through categorical variables and therefore could not be combined with the other studies.^25,26^ Both used healthcare providers as coaches and both found no significant differences between the intervention and control groups, which is consistent with the 2 continuous variable physical activity threshold studies.

##### Variation by Concordance

[underlined: Physical activity change]. Change was reported with the following concordance scores: 0-1 (n=2),^47,48^ 2 (n=4),^32,35,43,55^ 3 (n=2),^30,58^ and 4 (n=2).^29,31^ Figure 24 shows the forest plot organized by concordance score. Across the 4 scores, there were major differences in effect sizes (SMD range -0.05 to 0.54), but they did not form any type of consistent pattern by level of concordance score.

Figure 24 Effect of Health Coaching on Physical Activity Change by Concordance

[underlined: Physical activity threshold.] Threshold was reported in 5 studies,^20,21,45,54,61^ all of which had a concordance score of either 3 (n=3)^20,45,54^ or 4 (n=2).^21,61^ Again, no clear pattern emerged by level of concordance (Figure 25).

Figure 25 Effect of Health Coaching on Physical Activity Threshold by Concordance

The 2 trials^25,26^ that assessed physical activity threshold through categorical variables both had concordance scores of 0-1, and both found no significant differences between the intervention and control groups. This is different from the results for physical activity change, but still adds evidence to no specific pattern of effect for concordance score on physical activity change.

#### Effects on Weight Management

Twenty of the eligible RCTs examined the impact of health coaching on weight in pounds or kilograms (n=12), body mass index (BMI) (n=16), or both (n=8).^19,21,23,24,27,29,31-33,36,37,40,46,48,49,53,55-58^ As change in BMI was the most common metric across the 20 studies, we conducted quantitative synthesis for this outcome and stratified studies by the key moderators of interest. We provide a qualitative synthesis of findings for the 4 trials that reported outcomes as change in weight in kilograms or pounds only and could not be pooled with the other studies.

##### Variation by Population Characteristics

[underlined: Change in BMI]. Change was reported in the following medical conditions: diabetes^21,27,40,46,49,55,57,58^ (n=8), obesity^23,29,37,56^ (n=4), cardiovascular disease^53^ (n=1), metabolic syndrome^36^ (n=1), colorectal cancer^31^ (n=1), and “mixed conditions”^32^ (n=1). Figure 26 shows the forest plot organized by medical condition. No clear pattern of effects emerged. All subgroups demonstrated the same direction of effects. However, across the 6 populations, there were major differences in magnitude of effect sizes (MD range -1.40 to -0.10). Both pooled estimates of the diabetes and obesity subgroups displayed moderate to high heterogeneity as exhibited by an I^2^ >50%.

Figure 26 Effect of Health Coaching on Change in BMI by Population Characteristics

[underlined: Change in weight in kilograms]. There were 4 additional studies that presented data on weight in kilograms but not on BMI.^19,24,33,48^ These findings are synthesized qualitatively. Two studies were conducted in patients with obesity,^19,48^ one was conducted in patients with type 2 diabetes,^24^ and one study looked at the effect of the same intervention on 2 populations, one with type 2 diabetes and one with cardiovascular disease (CVD).^33^ Congruent with the BMI studies, no clear pattern emerged. The 2 obesity studies had conflicting results; one^48^ showed a positive effect of health coaching, while the other^19^ displayed a positive effect for the active control group. Consistent with the findings above, neither diabetes study^24,33^ found positive effects on weight loss in kilograms for health coaching. In addition, a study that also looked at CVD^33^ did not find a positive effect of health coaching in this population.

##### Variation by Dose

[underlined: Change in BMI]. The number of planned contacts ranged from 5 to 51. Figure 27 shows the forest plot organized by number of planned contacts. Dose was different for all studies except 2 sets of studies that had either 5 or 6 planned contacts. The median dose was 17 planned contacts. The MD range was -1.70 (a study with 24 planned contacts^37^) to 0.26 (a study with 17 planned contacts^46^). No clear pattern emerged from the data to demonstrate that number of planned contacts explained variation in effects of BMI across studies.

Figure 27 Effect of Health Coaching on BMI by Intervention Dose

[underlined: Change in weight in kilograms]. There were 4 additional studies that presented data on change in kilograms.^19,24,33,48^ The number of planned contacts ranged from 9 to 20 session, with a median dose was 12 planned contacts. Only the study with the greatest number of sessions (n=20) resulted in a statistically significant impact on weight change.^48^ The other 3 studies with doses of 9 or 12 contacts did not produce significant impacts on weight change.

##### Variation by Mode

There were 3 different major modes of intervention delivery for the studies that reported changes in BMI. Seven studies used primarily telephone-based delivery,^21,31,36,46,53,55,57^ and an additional 7 used primarily in-person coaching.^23,29,32,37,40,56,58^ The other 2 studies used a mix of intervention delivery modes.^27,49^ Figure 28 shows the forest plot organized by delivery mode. Both in-person and telephone delivery displayed a similar direction and magnitude of effects; however, only the telephone delivery estimate was statistically significant. Both estimates also had moderate to high heterogeneity. In contrast, the 2 studies that used a mix of intervention delivery modes displayed point estimates that were null.

Figure 28 Effect of Health Coaching on BMI by Mode of Delivery

[underlined: Change in weight in kilograms]. The 4 additional studies that presented data on weight change in kilograms^19,24,33,48^ were all delivered via telephone. Thus, we were unable to assess the impact of intervention mode on these studies.

##### Variation by Type of Individual Conducting Coaching Intervention

Studies employed a variety of personnel as health coaches. Nine used a nurse or other licensed healthcare provider as the coach.^21,23,27,32,36,53,55,56,58^ Two used a licensed behavioral health provider,^31,57^ and another 2 employed peer coaches.^46,49^ The final 3 studies used a variety of other personnel as coaches (eg, study-trained lifestyle coach).^29,37,40^ The direction and magnitude of effects were similar across all subgroups, except one (Figure 29). Nearly all subgroups displayed a small, positive impact on reductions in BMI. In contrast, both peer-led coaching interventions did not report reductions in BMI.

Figure 29 Effect of Health Coaching on BMI by Type of Coach

[underlined: Change in weight in kilograms]. The 4 additional studies that presented data on weight change in kilograms^19,24,33,48^ were all delivered by the following: certified health coach,^19^ study-trained coach,^33^ nurse,^24^ and a coach with an unspecified training or discipline.^48^ We were unable to assess the impact of intervention mode on these studies. Only the study with the coach of unclear training produced a statistically significant impact on reductions in weight.^48^

##### Variation by Concordance

Figure 30 shows the forest plot organized by concordance score. Qualitatively, no consistent pattern of effects by level of concordance score were found. All 3 pooled estimates for concordance scores of 4, 3, or 2 displayed a similar magnitude and direction of effects and one of the 2 studies with a concordance score of 0 produced one of the largest point estimates.^36^

Figure 30 Effect of Health Coaching on BMI by Concordance

[underlined: Change in weight in kilograms]. The 4 additional studies that presented data on weight change in kilograms^19,24,33,48^ had the following concordance scores: 2 had scores of 0,^33,48^ one had a score of 1,^24^ and one had a score of 4.^19^ Similar to the findings for BMI, no consistent pattern of effects by concordance score emerged. The only study with a statistically significant impact on reductions in weight^48^ had a concordance score of 0 while studies with scores of 4 did not produce significant impacts on weight loss.

#### Effects on Smoking Cessation

Two of the eligible RCTs examined the impact of health coaching on smoking behavior.^31,53^ Neither trial found an effect of health coaching on smoking behavior. Thus we were unable to explore variations in effects by the key moderators of interest.

#### Effects on Medication Adherence

Three of the eligible RCTs examined the impact of health coaching on medication adherence outcomes in patients with diabetes.^21,59,61^ Below we explore variations in effects by the key moderators.

##### Variation by Population Characteristics

All 3 studies examined the effects of health coaching on medication adherence in patients with type 2 diabetes.^21,59,61^ Thus we were unable to assess variation by population.

##### Variation by Dose

One study had fewer than 10 planned contacts^21^ and 2 studies had 10 or more planned contacts.^59,61^ The study with the highest number of planned contacts (16 contacts) was the only study to find a positive effect of health coaching on medication adherence.^59^

##### Variation by Mode

Of the 3 studies that focused on medication adherence, one delivered the health coaching intervention in-person and found a positive effect on the outcome of interest.^59^ The remaining 2 studies delivered the intervention via telephone and did not find a positive effect of health coaching on medication adherence.^21,61^

##### Variation by Type of Individual Conducting Coaching Intervention

All 3 studies used behavioral or healthcare providers to deliver the health coaching intervention. One study used trained medical assistants and found a positive effect of health coaching on medication adherence.^59^ The remaining 2 studies used either trained nurse educators^21^ or behavioral health providers (social workers or master's-level psychologists).^61^ Neither study found a positive effect of health coaching on medication adherence.

##### Variation by Concordance

All 3 studies had a concordance score of 4; thus we were unable to assess variation by this moderator.^21,59,61^

### Detailed Findings for Self-efficacy

Eight of the eligible RCTs examined the impact of health coaching interventions on self-efficacy outcomes.^22,24,34,35,45,54,62,63^ All 8 studies used questionnaires with continuous scales and were therefore amenable for quantitative synthesis. However, there was substantial variability in the questionnaires used to measure self-efficacy, so all summary estimates were calculated as SMDs.

#### Variation by Population Characteristics

To assess whether the effects of health coaching interventions vary by the medical condition of the population, we classified studies and organized findings by the following populations: diabetes^24,34,40,54,62^ (n=6), obesity,^22^ (n=1) and arthritis (n=1).^35^ We had sufficient studies to perform one meta-analysis on the group with diabetes. The other comparisons were synthesized qualitatively.

Figure 31 shows the forest plot of the meta-analysis and other effect sizes. Across the 3 populations, all effect sizes were positive and statistically significant, but varied in magnitude (SMD range 0.38 to 0.68). The pooled estimate for diabetes showed a small, positive effect size compared to the moderate effect sizes for the other 2 studies.

Figure 31 Effect of Health Coaching on Self-efficacy by Population Characteristics

#### Variation by Dose

To assess whether the effects of health coaching vary by intervention dose, we organized studies by number of planned sessions (range 9 to 72). Over the range of sessions, all SMDs found a small to moderate effect of health coaching on self-efficacy (SMD Range 0.11 to 0.68) and 6 of these results were significant. Figure 32 shows the forest plot for different intervention doses. The forest plot does not show any clear pattern by intervention dose.

Figure 32 Effect of Health Coaching on Self-efficacy by Intervention Dose

#### Variation by Mode

To assess whether the effects of health coaching interventions vary by the mode of delivery, we classified interventions as delivered either via telephone^24,34,45,62^ (n=4), in-person^22,40,54^ (n=3), or using mixed modes^35^ (n=1). Across the 3 subgroups, all effect sizes were in the same direction and of a similar small to moderate effect size (SMD range 0.39 to 0.68). Two were statistically significant (telephone and mixed mode) while the other trended toward significance (in-person) (Figure 33).

Figure 33 Effect of Health Coaching on Self-efficacy by Mode of Delivery

#### Variation by Type of Individual Conducting Coaching Intervention

To assess whether the effects of health coaching vary by the discipline of or type of training received by the coaches, we classified studies by type of interventionist: healthcare providers^22,34,40^ (n=3), “other”^24,35,62^ (n=3), behavioral health provider^45^ (n=1), or peer coaches^54^ (n=1). Across the 4 populations, all effect sizes were positive and of a similar small to medium size (SMD range 0.21 to 0.57), but only the “other” coach type subgroup was statistically significant (Figure 34).

Figure 34 Effect of Health Coaching on Self-efficacy by Type of Coach

#### Variation by Concordance

We classified studies by the concordance score (range 0-4) received in relation to the number of our key elements of health coaching contained. Four studies^22,34,40,62^ contained all 3 elements, scoring 4. Two studies received a score of 3^45,54^ and one study each a score of 2^35^ or 1.^24^ Figure 35 shows the forest plot grouped by concordance scores. Across the score categories, effect sizes were positive (SMD range 0.11 to 0.68), 2 of which were statistically significant. These results, however, do not show evidence of any linear pattern related to concordance score.

Figure 35 Effect of Health Coaching on Self-efficacy by Concordance

### Quality of Evidence for KQ 2

The same studies were included for KQs 1 and 2. The quality of evidence is discussed above in the KQ 1 section.