# REFERENCES

1 Yu W, Ravelo A, Wagner TH, . Prevalence and costs of chronic conditions in the VA health care system. Med Care Res Rev. 2003;60(3 Suppl):146S-167S.15095551
2 Ostbye T, Yarnall KS, Krause KM, Pollak KI, Gradison M, Michener JL. Is there time for management of patients with chronic diseases in primary care? Ann Fam Med. 2005;3(3):209-214.15928223
3 Schillinger D, Piette J, Grumbach K, . Closing the loop: physician communication with diabetic patients who have low health literacy. Arch Intern Med. 2003;163(1):83-90.12523921
4 Liddy C, Blazkho V, Mill K. Challenges of self-management when living with multiple chronic conditions: Systematic review of the qualitative literature. Canadian Family Physician. 2014;60(12):1123-1133.25642490
5 Zullig LL, Peterson ED, Bosworth HB. Ingredients of successful interventions to improve medication adherence. JAMA. 2013;310(24):2611-2612.24264605
6 Centers for Disease Control and Prevention. How much physcial activity do adults need? Available at: http://www.cdc.gov/physicalactivity/basics/adults/. Accessed December 16, 2015.
7 Sevick MA, Trauth JM, Ling BS, . Patients with Complex Chronic Diseases: perspectives on supporting self-management. J Gen Intern Med. 2007;22 Suppl 3:438-444.18026814
8 Lindner H, Menzies D, Kelly J, Taylor S, Shearer M. Coaching for behaviour change in chronic disease: A review of the literature and the implications for coaching as a self-management intervention. Aust J Prim Health. 2003;9:177-185.
9 Olsen JM, Nesbitt BJ. Health coaching to improve healthy lifestyle behaviors: an integrative review. Am J Health Promot. 2010;25(1):e1-e12.
10 Wolever RQ, Eisenberg DM. What is health coaching anyway?: standards needed to enable rigorous research. Arch Intern Med. 2011;171(22):2017-2018.21986348
11 Simmons LA, Wolever RQ. Integrative Health Coaching and Motivational interviewing: Synergistic Approaches to Behavior Change in Healthcare. Glob Adv Health Med. 2013;2(4):28-35.24416683
12 Butterworth S, Linden A, McClay W. Health Coaching as an Intervention in Health Management Programs. Disease Management & Health Outcomes. 2007;15(5):299-307.
13 Weiss KB. Managing complexity in chronic care: an overview of the VA state-of-the-art (SOTA) conference. J Gen Intern Med. 2007;22 Suppl 3:374-378.
14 Wolever RQ, Simmons LA, Sforzo GA, . A systematic review of the literature on health and wellness coaching: defining a key behavioral intervention in healthcare. Glob Adv Health Med. 2013;2(4):38-57.
15 Higgins J, Altman DG. Chapter 8: Assessing risk of bias in included studies. In Cochrane Handbook for Systematic Reviews of Interventions Version 5.0, 2008. Available at: http://handbook.cochrane.org/chapter_8/8_assessing risk of bias in included studies.htm (http://handbook.cochrane.org/chapter_8/8_assessing_risk_of_bias_in_included_studies.htm). Accessed August 5, 2016.
16 Lin PH, Yancy WS, Jr., Pollak KI, . The influence of a physician and patient intervention program on dietary intake. J Acad Nutr Diet. 2013;113(11): 1465-1475.23999279
17 Chang SM, Carey TS, Kato EU, Guise JM, Sanders GD. Identifying research needs for improving health care. Ann Intern Med. 2012;157(6):439-445.22847017
18 AHRQ. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD: Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed October 6, 2015.
19 Pearson ES, Irwin JD, Morrow D, Battram DS, Melling CW. The CHANGE program: comparing an interactive vs. prescriptive approach to self-management among university students with obesity. Can J Diabetes. 2013;37(1):4-11.24070742
20 Ruggiero L, Riley BB, Hernandez R, . Medical assistant coaching to support diabetes self-care among low-income racial/ethnic minority populations: randomized controlled trial. West J Nurs Res. 2014;36(9):1052-1073.24569698
21 Frosch DL, Uy V, Ochoa S, Mangione CM. Evaluation of a behavior support intervention for patients with poorly controlled diabetes. Arch Intern Med. 2011;171(22):2011-2017.21986347
22 Annesi JJ, Unruh JL, Marti CN, Gorjala S, Tennant G. Effects of the coach approach intervention on adherence to exercise in obese women: assessing mediation of social cognitive theory factors. Res Q Exerc Sport. 2011;82(1):99-108.21462690
23 Appel LJ, Clark JM, Yeh H-C, . Comparative effectiveness of weight-loss interventions in clinical practice. N Engl J Med. 2011;365(21):1959-1968.22085317
24 Blackberry ID, Furler JS, Best JD, . Effectiveness of general practice based, practice nurse led telephone coaching on glycaemic control of type 2 diabetes: the Patient Engagement and Coaching for Health (PEACH) pragmatic cluster randomised controlled trial. BMJ. 2013;347:f5272.24048296
25 Bostrom C, Elfving B, Dupre B, Opava CH, Lundberg IE, Jansson E. Effects of a one-year physical activity programme for women with systemic lupus erythematosus - a randomized controlled study. Lupus. 2016.
26 Brodin N, Eurenius E, Jensen I, Nisell R, Opava CH. Coaching patients with early rheumatoid arthritis to healthy physical activity: a multicenter, randomized, controlled study. Arthritis Rheum. 2008;59(3):325-331.18311770
27 Browning CJ, Yang H, Zhang T, . Implementing a chronic disease self-management program into china: the happy life club. Front Public Health. 2014;2:181.25964910
28 Cinar AB, Oktay I, Schou L. “Smile healthy to your diabetes”: health coaching-based intervention for oral health and diabetes management. Clin Oral Investig. 2014;18(7): 1793-1801.
29 Damschroder LJ, Lutes LD, Kirsh S, . Small-changes obesity treatment among veterans: 12-month outcomes. Am J Prev Med. 2014;47(5):541-553.25217098
30 Glasgow RE, Boles SM, McKay HG, Feil EG, Barrera M, Jr. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med. 2003;36(4):410-419 410p.12649049
31 Hawkes AL, Chambers SK, Pakenham KI, . Effects of a telephone-delivered multiple health behavior change intervention (CanChange) on health and behavioral outcomes in survivors of colorectal cancer: a randomized controlled trial. J Clin Oncol. 2013;31(18):2313-2321.23690410
32 Holland SK, Greenberg J, Tidwell L, Malone J, Mullan J, Newcomer R. Community-based health coaching, exercise, and health service utilization. J Aging Health. 2005;17(6):697-716.16377768
33 Karhula T, Vuorinen AL, Raapysjarvi K, . Telemonitoring and Mobile Phone-Based Health Coaching Among Finnish Diabetic and Heart Disease Patients: Randomized Controlled Trial. J Med Internet Res. 2015;17(6):e153.26084979
34 Kim MT, Kim KB, Huh B, . The Effect of a Community-Based Self-Help Intervention: Korean Americans With Type 2 Diabetes. Am J Prev Med. 2015;49(5):726-737.26184986
35 Knittle K, De Gucht V, Hurkmans E, . Targeting motivation and self-regulation to increase physical activity among patients with rheumatoid arthritis: a randomised controlled trial. Clin Rheumatol. 2015;34(2):231-238.24213780
36 Luley C, Blaik A, Gotz A, . Weight loss by telemonitoring of nutrition and physical activity in patients with metabolic syndrome for 1 year. J Am Coll Nutr. 2014;33(5):363-374.25105874
37 Ma J, Yank V, Xiao L, . Translating the Diabetes Prevention Program lifestyle intervention for weight loss into primary care: a randomized trial. JAMA Intern Med. 2013;173(2): 113-121.23229846
38 Azar KM, Xiao L, Ma J. Baseline obesity status modifies effectiveness of adapted diabetes prevention program lifestyle interventions for weight management in primary care. Biomed Res Int. 2013;2013:191209.24369008
39 McMurray SD, Johnson G, Davis S, McDougall K. Diabetes education and care management significantly improve patient outcomes in the dialysis unit. Am J Kidney Dis. 2002;40(3):566-575 510p.12200809
40 Nishita C, Cardazone G, Uehara DL, Tom T. Empowered diabetes management: life coaching and pharmacist counseling for employed adults with diabetes. Health Educ Behav. 2013;40(5):581-591.23174629
41 Patja K, Absetz P, Auvinen A, . Health coaching by telephony to support self-care in chronic diseases: clinical outcomes from The TERVA randomized controlled trial. BMC Health Serv Res. 2012; 12:147.22682298
42 Pearson ES, Irwin JD, Morrow D, Hall CR. The CHANGE program: comparing an interactive versus prescriptive obesity intervention on university students' self-esteem and quality of life. Appl Psychol Health Well Being. 2012;4(3):369-389.23081768
43 Pinto BM, Stein K, Dunsiger S. Peers promoting physical activity among breast cancer survivors: A randomized controlled trial. Health Psychology. 2015;34(5):463-472.25110844
44 Ruggiero L, Moadsiri A, Butler P, . Supporting diabetes self-care in underserved populations: a randomized pilot study using medical assistant coaches. Diabetes Educ. 2010;36(1): 127-131.20185612
45 Sacco WP, Malone JI, Morrison AD, Friedman A, Wells K. Effect of a brief, regular telephone intervention by paraprofessionals for type 2 diabetes. J Behav Med. 2009;32(4):349-359.19365719
46 Safford MM, Andreae S, Cherrington AL, . Peer Coaches to Improve Diabetes Outcomes in Rural Alabama: A Cluster Randomized Trial. Ann Fam Med. 2015; 13 Suppl 1:S18-26.26304967
47 Sandroff BM, Klaren RE, Pilutti LA, Dlugonski D, Benedict RH, Motl RW. Randomized controlled trial of physical activity, cognition, and walking in multiple sclerosis. J Neurol. 2014;261(2):363-372.24323244
48 Sherwood NE, Jeffery RW, Welsh EM, Vanwormer J, Hotop AM. The drop it at last study: six-month results of a phone-based weight loss trial. Am J Health Promot. 2010;24(6):378-383.20594094
49 Thom DH, Ghorob A, Hessler D, De Vore D, Chen E, Bodenheimer TA. Impact of peer health coaching on glycemic control in low-income patients with diabetes: a randomized controlled trial. Ann Fam Med. 2013;11(2): 137-144.23508600
50 Moskowitz D, Thom DH, Hessler D, Ghorob A, Bodenheimer T. Peer coaching to improve diabetes self-management: which patients benefit most? J Gen Intern Med. 2013;28(7):938-942.23404203
51 Turner BJ, Hollenbeak CS, Liang Y, Pandit K, Joseph S, Weiner MG. A randomized trial of peer coach and office staff support to reduce coronary heart disease risk in African-Americans with uncontrolled hypertension. J Gen Intern Med. 2012;27(10): 1258-1264.22570108
52 Vale MJ, Jelinek MV, Best JD, Santamaria JD. Coaching patients with coronary heart disease to achieve the target cholesterol: a method to bridge the gap between evidence-based medicine and the “real world”--randomized controlled trial. J Clin Epidemiol. 2002;55(3):245-252.11864795
53 Vale MJ, Jelinek MV, Best JD, . Coaching patients On Achieving Cardiovascular Health (COACH): a multicenter randomized trial in patients with coronary heart disease. Arch Intern Med. 2003;163(22):2775-2783.14662633
54 van der Wulp I, de Leeuw JR, Gorter KJ, Rutten GE. Effectiveness of peer-led self-management coaching for patients recently diagnosed with Type 2 diabetes mellitus in primary care: a randomized controlled trial. Diabet Med. 2012;29(10):e390-397.22414198
55 Varney JE, Weiland TJ, Inder WJ, Jelinek GA. Effect of hospital-based telephone coaching on glycaemic control and adherence to management guidelines in type 2 diabetes, a randomised controlled trial. Intern Med J. 2014;44(9):890-897.24963611
56 Wadden TA, Volger S, Sarwer DB, . A two-year randomized trial of obesity treatment in primary care practice. N Engl J Med. 2011;365(21):1969-1979.22082239
57 Wayne N, Perez DF, Kaplan DM, Ritvo P. Health Coaching Reduces HbA1c in Type 2 Diabetic Patients From a Lower-Socioeconomic Status Community: A Randomized Controlled Trial. J Med Internet Res. 2015;17(10):e224.26441467
58 Whittemore R, Melkus GD, Sullivan A, Grey M. A nurse-coaching intervention for women with type 2 diabetes. Diabetes Educ. 2004;30(5):795-804.15510531
59 Willard-Grace R, Chen EH, Hessler D, . Health coaching by medical assistants to improve control of diabetes, hypertension, and hyperlipidemia in low-income patients: a randomized controlled trial. Ann Fam Med. 2015;13(2):130-138.25755034
60 Thom DH, Willard-Grace R, Hessler D, . The impact of health coaching on medication adherence in patients with poorly controlled diabetes, hypertension, and/or hyperlipidemia: a randomized controlled trial. J Am Board Fam Med. 2015;28(1):38-45.25567821
61 Wolever RQ, Dreusicke M, Fikkan J, . Integrative health coaching for patients with type 2 diabetes: a randomized clinical trial. Diabetes Educ. 2010;36(4):629-639.20534872
62 Young H, Miyamoto S, Ward D, Dharmar M, Tang-Feldman Y, Berglund L. Sustained effects of a nurse coaching intervention via telehealth to improve health behavior change in diabetes. Telemed J E Health. 2014;20(9):828-834.25061688
63 Kreuter MW, Eddens KS, Alcaraz KI, . Use of cancer control referrals by 2-1-1 callers: a randomized trial. Am J Prev Med. 2012;43(6 Suppl 5):S425-434.23157761
64 Mozaffarian D, Benjamin EJ, Go AS, . Heart disease and stroke statistics--2015 update: a report from the American Heart Association. Circulation. 2015;131(4):e29-322.25520374
65 Ford ES, Li C, Zhao G, Pearson WS, Capewell S. Trends in the prevalence of low risk factor burden for cardiovascular disease among United States adults. Circulation. 2009;120(13):1181-1188.19752328
66 Lin JS, O'Connor E, Evans CV, Senger CA, Rowland MG, Groom HC. Behavioral counseling to promote a healthy lifestyle in persons with cardiovascular risk factors: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2014;161(8):568-578.25155549
67 Li J, Zheng H, Du HB, . The multiple lifestyle modification for patients with prehypertension and hypertension patients: a systematic review protocol. BMJ Open. 2014;4(8):e004920.
68 Kivela K, Elo S, Kyngas H, Kaariainen M. The effects of health coaching on adult patients with chronic diseases: a systematic review. Patient Educ Couns. 2014;97(2):147-157.25127667
69 Chodosh J, Morton SC, Mojica W, . Meta-analysis: chronic disease self-management programs for older adults. Ann Intern Med. 2005;143(6):427-438.16172441
70 Edelman D, Gierisch JM, McDuffie JR, Oddone E, Williams JW, Jr. Shared medical appointments for patients with diabetes mellitus: a systematic review. J Gen Intern Med. 2015;30(1):99-106.25107290
71 Bohannon RW. Number of pedometer-assessed steps taken per day by adults: a descriptive meta-analysis. Phys Ther. 2007;87(12):1642-1650.17911274
72 Demeyer H, Burtin C, Hornikx M, . The Minimal Important Difference in Physical Activity in Patients with COPD. PLoS One. 2016;11(4):e0154587.27124297
73 Norris SL, Lau J, Smith SJ, Schmid CH, Engelgau MM. Self-management education for adults with type 2 diabetes: a meta-analysis of the effect on glycemic control. Diabetes Care. 2002;25(7):1159-1171.12087014
74 Robinson KA, Saldanha IJ, McKoy NA. AHRQ Methods for Effective Health Care. Frameworks for Determining Research Gaps During Systematic Reviews. Rockville (MD): Agency for Healthcare Research and Quality (US); 2011.