# APPENDIX C STUDY QUALITY ASSESSMENT

RANDOMIZED CONTROLLED TRIALS

## QUALITY ASSESSMENT RESPONSE TABLE

For full study citations, please refer to the report's main reference list.

Study^a^ | 1a | 1b | 2a | 2b | 2b | 2b | 2b | 2c | 3a | 3b | 3c | 4 | 5 | 6 | Overall Risk of Bias Rating
Annesi 2011^22^ | UR | UR | NR | NR | NR | NR | NR | UR | NR | NR | UR | LR | LR | LR | HR
Appel 2011^23^ | LR | UR | LR | NR | NR | NR | NR | NR | LR | NR | NR | LR | LR | LR | UR
Blackberry 2013^24^ | LR | LR | LR | NR | NR | NR | NR | LR | LR | LR | LR | LR | LR | LR | LR
Bostrom 2016^25^ | LR | LR | NR | NR | HR | NR | NR | NR | NR | LR | NR | UR | LR | LR^b^ | LR
Brodin 2008^26^ | LR | HR | NR | NR | HR | NR | NR | NR | NR | LR | NR | HR | LR | LR | HR
Browning 2014^27^ | UR | UR | LR | NR | NR | NR | NR | NR | LR | NR | NR | LR | LR | LR^c^ | UR
Cinar 2014^28^ | UR | LR | LR | LR | UR | UR | UR | UR | LR | LR | LR | HR | LR | LR | UR
Damschroder 2014^29^ | LR | UR | HR | NR | HR | HR | NR | NR | HR | HR | NR | LR | LR | LR | HR
Frosch 2011^21^ | LR | LR | LR | HR | HR | HR | NR | NR | LR | HR | NR | UR | LR | LR | UR
Glasgow 2003^30^ | UR | UR | LR | NR | UR | UR | NR | NR | LR | UR | NR | LR | HR | HR | HR
Hawkes 2013^31^ | LR | LR | UR | NR | UR | UR | UR | NR | UR | UR | NR | LR | LR | LR | UR
Holland 2005^32^ | LR | UR | UR | NR | HR | NR | NR | NR | UR | UR | NR | UR | LR | LR | UR
Karhula 2015^33^ | LR | LR | LR | NR | NR | NR | NR | LR | LR | LR | LR | UR | UR | UR | UR
Kim 2015^34^ | HR | HR | LR | NR | NR | NR | NR | HR | LR | NR | HR | HR | LR | UR | HR
Knittle 2015^35^ | LR | LR | NR | NR | HR | NR | NR | HR | NR | LR | LR | LR | LR | LR | UR
Lin 2013^16^ | LR | LR | LR | NR | NR | LR | NR | NR | LR | LR | NR | LR | LR | LR | LR
Luley 2014^36^ | UR | UR | LR | NR | HR | HR | NR | NR | LR | LR | NR | LR | LR | LR | HR
Ma 2013^37^ (Azar 2013^38^) | LR | LR | LR | NR | NR | NR | NR | NR | UR | NR | NR | LR | LR | LR | LR
McMurray 2002^39^ | LR | UR | UR | UR | NR | NR | NR | NR | LR | NR | NR | UR | LR | LR | UR
Nishita 2013^40^ | LR | LR | HR | NR | NR | NR | NR | HR | LR | NR | LR | LR | LR | LR | UR
Patja 2012^41^ | LR | UR | LR | NR | NR | NR | UR | UR | UR | UR | UR | HR | LR | LR | UR
Pearson 2013^19^ (Pearson 2012^42^) | UR | UR | UR | NR | NR | UR | NR | NR | UR | UR | NR | HR | UR | LR | HR
Pinto 2015^43^ | UR | LR | NR | NR | UR | NR | NR | NR | NR | UR | NR | LR | LR | LR | HR
Ruggiero 2010^44^ | UR | UR | LR | NR | NR | NR | NR | NR | LR | NR | NR | UR | LR | LR | UR
Ruggiero 2014^20^ | LR | UR | LR | NR | UR | UR | NR | NR | LR | UR | NR | HR | UR | LR | HR
Sacco 2009^45^ | HR | UR | LR | NR | UR | UR | NR | UR | LR | UR | UR | UR | LR | LR | UR
Safford 2015^46^ | LR | UR | LR | NR | NR | NR | NR | HR | LR | NR | HR | HR | LR | LR | HR
Sandroff 2014^47^ | LR | LR | HR | NR | HR | NR | NR | NR | HR | HR | NR | HR | LR | LR | HR
Sherwood 2010^48^ | UR | UR | UR | NR | NR | NR | NR | NR | UR | UR | NR | UR | UR | UR | HR
Thom 2013 #375^49^ (Moskowitz 2103^50^) | UR | LR | LR | NR | NR | NR | NR | NR | LR | NR | NR | HR | LR | LR | UR
Turner 2012^51^ | LR | LR | LR | HR | NR | NR | HR | NR | LR | UR | NR | LR | UR | LR | LR
Vale 2002^52^ | LR | LR | HR | NR | NR | NR | NR | NR | LR | UR | NR | LR | UR | LR | UR
Vale 2003^53^ | LR | LR | LR | NR | HR | LR | LR | NR | LR | LR | NR | LR | LR | LR | LR
Van der Wulp 2012^54^ | LR | LR | NR | NR | UR | UR | NR | UR | NR | UR | UR | UR | UR | UR | UR
Varney 2014^55^ | LR | LR | LR | NR | HR | NR | NR | NR | LR | HR | NR | HR | UR | HR | HR
Wadden 2011^56^ | LR | UR | UR | NR | NR | NR | NR | NR | UR | NR | NR | LR | LR | LR | UR
Wayne 2015^57^ | LR | LR | LR | NR | NR | NR | NR | NR | LR | NR | NR | HR | LR | UR | UR
Whittemore 2004^58^ | UR | UR | LR | NR | HR | HR | NR | NR | LR | HR | NR | UR | LR | LR | HR
Willard-Grace 2015^59^ (Thom 2015^60^) | LR | LR | LR | HR | NR | NR | NR | NR | LR | HR | NR | UR | LR | LR | UR
Wolever 2010^61^ | UR | UR | LR | UR | UR | NR | NR | NR | LR | LR | NR | LR | LR | LR | UR
Young 2014^62^ | UR | UR | NR | NR | UR | NR | NR | UR | NR | UR | UR | LR | HR | LR | UR

Abbreviations: UR=Unclear risk, LR=Low risk, HR=High risk, NR=Not reported

a The companion paper (noted in parentheses) is not rated separately in this table.

b Recall bias

c Contamination