# APPENDIX A SEARCH STRATEGY

PubMed: 12/14/2015

Set | Terms | Results
1 | “Wellness coach”[tiab] OR “wellness coaching”[tiab] OR “health coach”[tiab] OR “health coaching”[tiab] OR “peer coach”[tiab] OR “peer coaching”[tiab] | 389
2 | coaching[tiab] OR coach[tiab] | 4710
3 | “Health Education”[Mesh] OR “Health Promotion”[Mesh] OR “Motivational Interviewing”[Mesh] OR “Health Behavior”[Mesh] OR “Health Knowledge, Attitudes, Practice”[Mesh] OR “Counseling”[Mesh] OR “Peer Group”[Mesh] OR “Social Support”[Mesh] OR “Self Care”[Mesh] OR “Patient Education as Topic”[Mesh] OR “Exercise”[Mesh] OR “Exercise Therapy”[Mesh] OR “Weight Loss”[Mesh] OR “Nutrition Therapy”[Mesh] OR “Chronic Disease/prevention and control”[Mesh] OR “Chronic Disease/rehabilitation”[Mesh] OR “health education”[tiab] OR “patient education”[tiab] OR “motivational interviewing”[tiab] OR attitudes[tiab] OR attitude[tiab] OR counseling[tiab] OR “social support”[tiab] OR “psychosocial support”[tiab] OR “self care”[tiab] OR “self-efficacy”[tiab] OR “self management”[tiab] OR “physical activity”[tiab] OR “weight loss”[tiab] OR exercise[tiab] OR fitness[tiab] OR nutrition[tiab] | 1153106
4 | #2 AND #3 | 2044
5 | #1 OR #4 | 2119
6 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR “Comparative Study”[Publication Type] OR “Controlled Clinical Trial”[Publication Type] OR Nonrandom[tiab] OR non-random[tiab] OR nonrandomized[tiab] OR non-randomized[tiab] OR nonrandomized[tiab] OR non-randomised[tiab] OR “pre-post”[tiab] OR “post-test”[tiab] OR “post test”[tiab] OR pretest[tiab] OR pre-test[tiab] OR “pre test”[tiab] OR quasi-experiment*[tiab] OR quasiexperiment*[tiab] OR quasirandom*[tiab] OR quasi-random*[tiab] OR quasi-control*[tiab] OR quasicontrol*[tiab] OR (controlled[tiab] AND (trial[tiab] OR study[tiab]))) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 2902653
7 | #5 AND #6 | 927
8 | #7 limit to 2000 – present | 891

Embase: 12/14/2015

Set | Terms | Results
1 | ‘Wellness coach’:ti,ab OR ‘wellness coaching’:ti,ab OR ‘health coach’:ti,ab OR ‘health coaching’:ti,ab OR ‘peer coach’:ti,ab OR ‘peer coaching’:ti,ab | 494
2 | Coaching:ti,ab OR coach:ti,ab | 6298
3 | ‘health education’/exp OR ‘health promotion’/exp OR ‘motivational interviewing’/exp OR ‘health behavior’/exp OR ‘attitude to health’/exp OR ‘counseling’/exp OR ‘peer group’/exp OR ‘social support’/exp OR ‘self care’/exp OR ‘patient education’/exp OR ‘exercise’/exp OR ‘kinesiotherapy’/exp OR ‘weight reduction’/exp OR ‘diet therapy’/exp OR ‘chronic disease’/exp/dm_rh,dm_dm,dm_pc OR ‘health education’:ti,ab OR ‘patient education’:ti,ab OR ‘motivational interviewing’:ti,ab OR attitudes:ti,ab OR attitude:ti,ab OR counseling:ti,ab OR ‘social support’:ti,ab OR ‘psychosocial support’:ti,ab OR ‘self care’:ti,ab OR ‘self-efficacy’:ti,ab OR ‘self management’:ti,ab OR ‘physical activity’:ti,ab OR ‘weight loss’:ti,ab OR exercise:ti,ab OR fitness:ti,ab OR nutrition:ti,ab | 1754744
4 | #2 AND #3 | 2946
5 | #1 OR #4 | 3048
6 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ti,ab OR factorial*:ti,ab OR crossover*:ti,ab OR (cross NEAR/1 over*):ti,ab OR placebo*:ti,ab OR (doubl* NEAR/1 blind*):ti,ab OR (singl* NEAR/1 blind*):ti,ab OR assign*:ti,ab OR allocat*:ti,ab OR volunteer*:ti,ab OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp OR (controlled:ti,ab AND (trial:ti,ab OR study:ti,ab)) OR (non NEAR/1 random*):ti,ab OR (quasi NEAR/1 experiment*):ti,ab OR (quasi NEAR/1 random*):ti,ab OR (quasi NEAR/1 control*):ti,ab OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ti,ab OR ‘comparative studies’:ti,ab OR nonrandom*:ti,ab OR ‘pre-post’:ti,ab OR ‘post test’:ti,ab OR pretest:ti,ab OR pre-test:ti,ab OR ‘pre test’:ti,ab OR quasiexperiment*:ti,ab OR quasirandom*:ti,ab OR quasicontrol*:ti,ab NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp) AND [humans]/lim | 6095040
7 | #5 AND #6 | 1388
8 | [embase]/lim NOT [medline]/lim
9 | #7 AND #8 | 560
10 | #9 limit to 2000 – present | 552

CINAHL: 12/14/2015

Set | Terms | Results
1 | TI (“Wellness coach” OR “wellness coaching” OR “health coach” OR “health coaching” OR “peer coach” OR “peer coaching”) OR AB (“Wellness coach” OR “wellness coaching” OR “health coach” OR “health coaching” OR “peer coach” OR “peer coaching”) | 305
2 | TI (coaching OR coach) OR AB (coaching OR coach) | 4864
3 | (MH “Health Education+”) OR (MH “Health Promotion+”) OR (MH “Motivational Interviewing”) OR (MH “Health Behavior+”) OR (MH “Attitude to Health+”) OR (MH “Health Knowledge”) OR (MH “Counseling+”) OR (MH “Peer Group”) OR (MH “Support, Psychosocial+”) OR (MH “Social Environment+”) OR (MH “Self Care+”) OR (MH “Patient Education+”) OR (MH “Exercise+”) OR (MH “Therapeutic Exercise+”) OR (MH “Weight Loss+”) OR (MH “Diet Therapy+”) OR (MH “Chronic Disease/PC”) OR (MH “Chronic Disease/RH”) OR TI (“health education” OR “patient education” OR “motivational interviewing” OR attitudes OR attitude OR counseling OR “social support” OR “psychosocial support” OR “self care” OR “self-efficacy” OR “self management” OR “physical activity” OR “weight loss” OR exercise OR fitness OR nutrition) OR AB (“health education” OR “patient education” OR “motivational interviewing” OR attitudes OR attitude OR counseling OR “social support” OR “psychosocial support” OR “self care” OR “self-efficacy” OR “self management” OR “physical activity” OR “weight loss” OR exercise OR fitness OR nutrition) | 612054
4 | #2 AND #3 | 2379
5 | #1 OR #4 | 2438
6 | (MH “Clinical Trials+”) OR PT Clinical trial OR PT randomized controlled trial OR TX clinic* n1 trial* OR TX ( (singl* n1 blind*) OR (singl* n1 mask*) ) OR TX ( (doubl* n1 blind*) OR (doubl* n1 mask*) ) OR TX ( (tripl* n1 blind*) OR (tripl* n1 mask*) ) OR TX ( (trebl* n1 blind*) OR (trebl* n1 mask*) ) OR (MH “Random Assignment”) OR (MH “Quantitative Studies”) OR TI (randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR groups) OR AB (randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR groups) OR TI (Nonrandom OR non-random OR nonrandomized OR non-randomized OR nonrandomized OR non-randomised) OR AB (Nonrandom OR non-random OR nonrandomized OR non-randomized OR nonrandomized OR non-randomised) OR (MH “Comparative Studies”) OR (MH “Quasi-Experimental Studies+”) OR TI (“pre-post” OR “post-test” OR “post test” OR pretest OR pre-test OR “pre test” OR quasi-experiment* OR quasiexperiment* OR quasirandom* OR quasi-random* OR quasi-control* OR quasicontrol* OR (controlled AND (trial OR study))) OR AB (“pre-post” OR “post-test” OR “post test” OR pretest OR pre-test OR “pre test” OR quasi-experiment* OR quasiexperiment* OR quasirandom* OR quasi-random* OR quasi-control* OR quasicontrol* OR (controlled AND (trial OR study))) NOT (PT editorial OR PT letter OR PT case study OR PT commentary) | 1371759
7 | #5 AND #6 | 1288
8 | #7 limit to 2000 – present | 1239

PsycINFO: 12/14/2015

Set | Terms | Results
1 | TI ( “wellness coach” OR “wellness coaching” OR “health coach” OR “health coaching” OR “peer coach” OR “peer coaching” ) OR AB ( “wellness coach” OR “wellness coaching” OR “health coach” OR “health coaching” OR “peer coach” OR “peer coaching” ) | 303
2 | TI (coaching OR coach) OR AB (coaching OR coach) | 11927
3 | DE “Health Education” OR DE “Health Promotion” OR DE “Motivational Interviewing” OR DE “Health Behavior” OR DE “Health Knowledge” OR DE “Health Attitudes” OR DE “Counseling” OR SU counseling OR DE “Peer Relations” OR DE “Peer Pressure” OR DE “Peers” OR DE “Social Support” OR DE “Support Groups” OR DE “Self-Care Skills” OR DE “Client Education” OR DE “Exercise” OR DE “Aerobic Exercise” OR DE “Weight lifting” OR DE “Yoga” OR DE “Movement Therapy” OR DE “Weight Loss” OR DE “Diets” OR TI (“health education” OR “patient education” OR “motivational interviewing” OR attitudes OR attitude OR counseling OR “social support” OR “psychosocial support” OR “self care” OR “self-efficacy” OR “self management” OR “physical activity” OR “weight loss” OR exercise OR fitness OR nutrition) OR AB (“health education” OR “patient education” OR “motivational interviewing” OR attitudes OR attitude OR counseling OR “social support” OR “psychosocial support” OR “self care” OR “self-efficacy” OR “self management” OR “physical activity” OR “weight loss” OR exercise OR fitness OR nutrition) | 472340
4 | #2 AND #3 | 2605
5 | #1 OR #4 | 2739
6 | ZC “treatment outcome/clinical trial”OR DE “Clinical Trials” OR TI (randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR trials OR groups) OR AB (randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR trials OR groups) OR TI (“comparative study”) OR AB (“comparative study”) OR TI (Nonrandom OR non-random OR nonrandomized OR non-randomized OR nonrandomized OR non-randomised OR “pre-post” OR “post-test” OR “post test” OR pretest OR pre-test OR “pre test” OR quasi-experiment* OR quasiexperiment* OR quasirandom* OR quasi-random* OR quasi-control* OR quasicontrol* OR (controlled AND (trial OR study)))) OR AB (Nonrandom OR non-random OR nonrandomized OR non-randomized OR nonrandomized OR non-randomised OR “pre-post” OR “post-test” OR “post test” OR pretest OR pre-test OR “pre test” OR quasi-experiment* OR quasiexperiment* OR quasirandom* OR quasi-random* OR quasi-control* OR quasicontrol* OR (controlled AND (trial OR study)))) AND (ZZ “journal article”) | 877890
7 | #5 AND #6 | 893
8 | #7 limit to 2000 – present; limit to human | 784