# SUMMARY AND DISCUSSION

Disparities in health between people with and without mental illness are common.20,28 The burden of medical illnesses, such as diabetes and cardiovascular disease, disproportionately affect people with mental illness.1-3 We identified 26 articles describing 23 unique studies that examined whether disparities in care exist for patients with mental health disorders regarding 3 preventive services—cancer screening (n=7), receipt of immunizations (n=3), and screening for tobacco use and referral for treatment (n=2)—and the management of 3 chronic diseases—type 2 diabetes mellitus (n=14), hypertension (n=2), and ischemic heart disease (n=1). The mental health conditions examined were those of most interest to our stakeholders due to their prevalence in Veterans or cost to the VA healthcare system; however, the majority of studies described the subjects with composite mental health disorders vs those without mental health disorders (n=17). Most of these studies used cross-sectional (n=11) or retrospective cohort (n=10) designs; 2 were prospective cohort studies. Approximately half of all included studies (n=12) studies were conducted within the VA healthcare system. Participants were typically midlife, the majority of whom were white. The composition of the included studies varied widely due to inclusion of studies of sex-specific outcomes (eg, breast cancer) or predominantly male populations (VA healthcare databases).

For observational studies, the strength of the evidence (SOE) is set initially at “low” and upgraded only for methodologically strong studies with large effects, or a strong dose-response pattern. The SOE rating may be decreased to “very low” for important risk of bias, inconsistent results, imprecise results, indirect evidence, or evidence of reporting bias. Since none of the outcomes met the upgrade criteria, the SOE for all outcomes was low or very low. Thus, our confidence in the effect estimates is limited: the true effect may be substantially different from the estimates presented here. Further research is very likely to have an important impact on our confidence in the estimates of effect and is likely to change those estimates.

## SUMMARY OF EVIDENCE BY KEY QUESTION

Overall, we found weak signals to support disparities in quality of care; however, results were inconsistent, and beyond diabetes care, the existing literature was sparse. Below we summarize the major findings for each outcome organized by condition and by type of outcome. We highlight key differences in findings between studies conducted inside the VA with VA users and those conducted outside the VA in community healthcare settings or with population-level datasets.

### Key Question 1a Disparities by Mental Health Status for Receipt of Appropriate Preventive Care Services and Indicated Screenings

A table summarizing our findings for receipt of appropriate preventive services is provided in Appendix F.

#### Cancer Screening

We identified one prospective cohort, 3 retrospective cohort, and 3 cross-sectional studies that addressed cancer screening among individuals with mental illness compared to those without mental illness.22-24,34-37 Most studies (n=4) addressed all 3 types of cancer screening.22,23,34,37 Total NOS scores ranged from 5 to 7, suggesting that studies were of fair quality. While we had sufficiently homogeneous studies to conduct meta-analyses for studies addressing disparities in breast, cervical, or colorectal cancer screening among those with depressive disorders compared to those without depression but, cervical cancer screening was the only area where the meta-analysis displayed low to moderate heterogeneity. Meta-analysis of 3 studies demonstrated that women with a diagnosis of depression were less likely to have cervical cancer screenings (OR 0.87; 95% CI, 0.77 to 0.98; I^2^=6.3%).

Existing evidence suggests small to moderate disparities in cancer screening for people with mental illness. Nearly all studies displayed a similar pattern of a negative association between having a mental health diagnosis and receipt of cancer screenings; however, several comparisons were not statically significant. The studies conducted that assessed the odds of breast, cervical, and colorectal cancer screening among VA users with and without mental illness displayed a similar pattern of negative associations. Results, however, were inconsistent. Two studies with VA users addressed all 3 cancers of interest among individuals with broadly defined mental illness compared to those without mental illness,23,37 and one assessed disparities in colorectal cancer screening only.24 The first VA study used national data on 113,495 VA users23 and reported significantly lower odds of mammography, Pap smears, and colorectal cancer screening among Veterans with mental illness. Yet, a second smaller VA study using only state-level data on 606 Veterans in the New Mexico VA healthcare system database37 reported no significant difference for mammography, Pap smears, or colorectal cancer screening among Veterans with mental illness. The last VA study provided estimates for receipt of colorectal cancer screening for those with PTSD, psychotic disorders, depression, or any mental health diagnosis.24 There was a significant and negative association between mental health diagnosis and receipt of colorectal cancer screening for all groups except those with PTSD.

#### Immunizations

We identified a total of 3 cross-sectional studies that compared vaccination use of those with mental illness and those without. Total NOS scores ranged from 5 to 7, suggesting that studies were of fair quality. All 3 studies addressed influenza vaccination, while 2 studies also addressed pneumococcal vaccination. Limited evidence existence to support small to moderate disparities in vaccination; however, results are inconsistent and the existing U.S.-based literature is small. The 2 studies of older adult and high risk sub-populations22,23 found evidence to support disparities in receipt of influenza vaccinations, while another study found no significant differences in self-reported receipt of influenza vaccinations38 among a general population of adults. Of the 2 studies that assessed ever receiving pneumococcal vaccinations, one medical chart based study among VA users reported that patient with a psychiatric diagnoses had a lower probability of receiving a pneumococcal vaccine than patients without a psychiatric diagnosis.23 In contrast, another study conducted outside the VA reported that those with depression were no less likely to report receiving a pneumococcal vaccine than those without depression but this study did not control of the presence of other mental illnesses in the comparator.22

#### Screening and Referral for Tobacco Use

Overall, there is limited comparative evidence to describe disparities in tobacco use processes of care indicators between those with mental illness and those without mental illness. We identified only 2 comparative studies that assessed screening for tobacco use and referral for smoking cessation treatment23,39; no identified study directly reported on prescriptions for smoking cessation pharmacotherapy. Both studies received total NOS scores of 5, suggesting studies of fair quality. Both identified studies were conducted with VA users. The available evidence suggests those with mental illness are more likely to be screened for tobacco use and referred for counseling than those without mental illness. This result is based on a single cross-sectional study. One cross-sectional study suggests that smokers with PTSD and depressive disorders are more likely to receive a physician’s recommendation for smoking cessation medications than those without mental illness; smokers with PTSD were also more likely to report that a physician had discussed quitting methods with them. Smokers with schizophrenia report that they may be less likely to receive advice to quit from physicians compared to smokers without a mental health diagnosis; however, no significant differences were found for having a physician discuss quitting methods or having a physician recommend medication for smoking cessation. No differences were found between smokers with a diagnosis of bipolar disorder and those without a mental health diagnosis for receipt of smoking cessation services.

### Key Question 1b Disparities by Mental Health Status in Management of Chronic Conditions

A table summarizing our findings for management of chronic conditions is provided in Appendix F.

#### Diabetes Care

We identified 14 studies (1 prospective cohort, 6 retrospective cohort, 7 cross-sectional) described in 16 papers that met inclusion criteria and compared diabetes process of care outcomes (eg, HbA1c testing, LDL-C at goal) among those with mental illness and those without mental illness.38,40-54 All studies were of fair (n= 11) to high (n=3) quality (NOS scores ≥5). Seven studies were conducted exclusively with patients who seek care in the VA healthcare system.41,44,45,47-49,51 Most studies addressed multiple quality indicators of diabetes. While several studies addressed depressive disorders, SMI, or composite groups of diabetic patients with mental illness, only one study47 assessed the specific impact of PTSD on diabetes quality of care indicators. Half of the studies were of fair to high quality (NOS scores ≥7). We had sufficiently homogeneous studies to conduct 8 meta-analyses; however, all but one pooled analysis displayed high heterogeneity (I^2^ ≥75%).

For most outcomes, results were inconsistent and suggest small to modest disparities in diabetes care for people with mental illness. We observed some qualitative differences in care patterns for studies conducted inside the VA healthcare system versus outside the VA healthcare system. For composite indicators of diabetes care, the one study conducted outside the VA reported a statistically significant and negative association, while 2 studies conducted with VA users reported mixed results for patients diagnosed with mental illnesses. There was a positive trend of more HbA1c monitoring for VA users with SMI compared to VA users without SMI,45,48 but results were inconsistent in the non-VA studies.42,50 The trend was reversed for diabetic eye exams. The one VA study that assessed receipt of eye exams among diabetic VA users with SMI45 compared to those without mental illness reported that patients with SMI were statistically significantly less likely to received eye exams than VA users without mental illness. In contrast, the 2 studies that assessed receipt of eye exams outside the VA42,50 found that diabetic patients with SMI were more likely to received eye exams than those without mental illness diagnoses, but only one estimate was statistically significant. Patterns for receipt of diabetic foot exams were similar inside and outside the VA; patients with mental illnesses were less likely to received foot exams compared to those without mental illness, but estimates were only significant for those patients seeking care inside the VA. Three VA studies41,45,48 assessed the adequacy of LDL-C control among patients with SMI and found no significant differences between VA users with and without SMI. Yet, the one study that provided comparative estimates outside the VA46 reported significant and negative effects of SMI on achieving adequate LDL-C control. Patterns for receipt of diabetic foot exams were similar inside and outside the VA; patients with mental illness were less likely to receive foot exams compared to those without mental illness, but estimates were statistically significant only for those patients seeking care inside the VA.

#### Hypertension Care

There is limited comparative evidence to describe disparities in hypertension process of care indicators between those with mental illness and those without mental illness. We identified only 2 studies (1 retrospective cohort, 1 cross-sectional) that met inclusion criteria that compared the adequacy of blood pressure control for hypertensive persons among those with mental illness and those without mental illness.45,55 Quality ratings were 7 points55 and 6 points.45, suggesting fair quality studies. Both studies were conducted with VA healthcare users. These studies examined a set threshold (ie, BP <140/90) to determine adequacy of blood pressure control. No statistically significant differences in adequacy of blood pressure control between individuals with and without mental illness diagnoses were reported in either study.

#### Ischemic Heart Disease Care

We identified only one study the met inclusion criteria and compared receipt of care post myocardial infarction between individuals with and without SMI.57 The included study received a total of 7 points on the NOS suggesting fair quality. This study of a Medicaid population in one eastern state (Maryland) from 1994-2004 found no differences in receipt of appropriate pharmacotherapy or rate of invasive intervention procedures post myocardial infarction between individuals with and without SMI.

### Key Question 2 Interaction Effect of Mental Health Status by Race/Ethnicity, Veteran Status, Geographic Location, Sex, or Sexual Orientation

We identified one cross-sectional study of fair quality with 2 separately published analyses assessing the interaction of mental health status and key subgroups of interest (race/ethnicity, geographic setting) for process of care indicators for diabetes and hypertension. No significant differences were noted for either subgroup. There were no analyses for the subgroups of interest in the eligible studies for cancer screening, immunizations, tobacco screening and referral, and ischemic heart disease. No identified studies conducted subgroup analyses by sex, sexual orientation, or Veteran status.

## CLINICAL AND POLICY IMPLICATIONS

Overall, the current state of the evidence regarding quality indicators of healthcare among individuals with mental illness is limited, due both to relatively few studies meeting our study criteria and the inconsistency of the results of the included studies. Our inconsistent findings are generally consistent with findings of prior comparative systematic reviews on the quality of medical care for people with and without mental illness.20,21 The relative lack of robust evidence supporting diminished quality of care delivered to individuals with mental illness should be interpreted cautiously. The tracer conditions (diabetes, ischemic heart disease, hypertension) and preventive services (cancer screening, screening for tobacco use and treatment referrals, immunizations) chosen for this study represent a very small proportion of the overall quality of healthcare indicators. Tracer conditions are chosen due to, among other factors, the ease with which adherence to standards of care can be documented and measured. New interventions designed to mitigate disparities in quality of care identified by these tracer conditions may not be generalizable to other conditions for which quality of care is more difficult to measure.

Variables potentially affecting the study results are the variety of different mental disorders studied, the complexity of the interventions evaluated, and the degree of involvement required by various healthcare providers and patients in completing the range of screening and treatment procedures. Groups of individuals with various types of mental illnesses, while clearly not homogeneous, may have different needs for interaction with the healthcare system. For example, individuals with depression may need increased motivation to complete recommended tests, while those with disorders of thought and perception (eg, schizophrenia) may need more detailed explanations of health conditions and instructions for follow up. In contrast, persons with SMI, once identified, may need to be followed more closely. Enhanced monitoring may influence how often they see a healthcare provider, possibly increasing opportunity for preventive intervention. With regard to intervention complexity, some of the interventions studied (eg, documentation of screening for smoking, prescription of a guideline concordant medication) can be completed in one step, whereas others (eg, completing a mammogram or colonoscopy) require more steps, including steps that occur outside of the initial clinical visit. Related to this point is the variation in the number and type of individuals involved with completion of the various interventions. For example, while completing a colonoscopy typically requires a primary care provider to order the test, a gastroenterologist to administer and interpret the test, and the patient to complete a bowel regimen in preparation for the test, an intervention like a recommendation to quit smoking can be completed by a wider variety of different healthcare providers (eg, primary care providers, psychiatrists or other mental health providers, nurses) and requires no action on the part of the patient (ie, when the outcome measured is simply receipt of the recommendation).

Implementation of the findings of this review should be pursued in concert with operational leaders and policy makers, including Primary Care and Mental Health Services within the Office of Patient Care Services, the Office of Mental Health Operations, National Center for Health Promotion and Prevention, and the newly established Office of Health Equity, as well as Veteran end-users. Developing best practices for the effective and sensitive care of patients with complex medical and behavioral health risks and comorbidities will require cross-disciplinary collaboration and problem-solving and, in many cases, cultural shifts within care environments.58 Diverse and flexible treatment models may be necessary to accommodate different care settings (eg, rural) within the VA healthcare system and individual patient preferences.

## LIMITATIONS

Our review has a number of strengths, including a protocol-driven design, a comprehensive search, and a careful quality assessment. We conducted both quantitative and qualitative synthesis when possible. Prior reviews on this topic have only used qualitative synthesis.

Our review, and the literature, also have limitations. First, we selected studies that included adults with bipolar disorder, schizophrenia, schizoaffective disorder, major depressive disorder (or depressive disorders), and PTSD. We selected these mental health conditions either because they are common in (eg, depressive disorders) or costly for (eg, schizophrenia) the VA healthcare system. For mixed study populations, ≥65% of the total population with mental health diagnoses was required to have a diagnosis of primary interest. The majority of studies combined mental health diagnoses (ie, evaluated a comparison of mental illness present vs absent). Unfortunately, such analyses do not provide adequate granularity to inform practice or policy. It is also important to note that we only included studies that recruited insured populations. If studies included mixed populations of insured and uninsured individuals, the study could only be included if the analysis controlled for insurance status, results were reported separately by insurance status, or ≥80% of total population had insurance. These eligibility requirements may have excluded some studies; however, we sought to include studies that were of greatest applicability to the VA healthcare system. Second, as expected, we identified only observational studies. Even the highest quality observational studies are susceptible to multiple forms of bias. Third, confounding is another major limitation of observational studies. Most included studies adjusted for multiple likely sources of confounding, but the majority of studies did not control for our a priori set of minimal covariates (ie, age, race/ethnicity, sex, and socioeconomic status or reasonable proxy for socioeconomic status like educational attainment). When possible, we used the most adjusted point estimates in our meta-analyses. However, these covariates were not consistent between studies. Fourth, we found significant heterogeneity in many of the planned meta-analyses we conducted. There are multiple potential sources of this heterogeneity. Variability in pooled effects is likely due to a combination of factors, and the limited number of studies precluded meta-regression. Fifth, we found limited data on certain populations (patients with PTSD) and outcomes (quality indicators for ischemic heart disease). Next, the poor/fair/high descriptors for the NOS scores, while reasonable, have not been validated. Finally, the lack of subgroup or interaction analyses for key subgroups of interest limits interpretation for these groups.

## RESEARCH GAPS/FUTURE RESEARCH

This comprehensive review of the literature identified several gaps in the current state of the evidence that warrant future investigation. We used the framework recommended by Robinson et al59 to identify gaps in evidence and classify why these gaps exist (Table 8). This approach considers PICOTS (population, intervention, comparator, outcomes, timing, and setting) to identify gaps and classifies them as due to (1) low strength of evidence or imprecise information, (2) biased information, (3) inconsistency or unknown consistency, and (4) not the right information. VA and other healthcare systems should consider their clinical and policy needs when deciding whether to invest in research to address gaps in evidence.

Table 8 Evidence Gaps and Future Research

Evidence Gap | Reason | Type of Studies to Consider
Limited to no comparative evidence for these populations:; - People with PTSD; - People with bipolar disorder; - Lesbian, gay, and transgender patients with mental illness | Low strength of evidence Limited information | High-quality cross-sectional or cohort studies in broad populations Observational comparative effectiveness studies
Limited or inconsistent comparative evidence for those with and without mental illness for these interventions or outcomes:; - Ischemic heart disease care; - Screening and treatment for smoking cessation; - Immunizations; - Hypertension | Low strength of evidence Inconsistency | High-quality cross-sectional or cohort studies in broad populations Observational comparative effectiveness studies
Comparative studies that explore interaction effects of, or subgroup analyses by sex, race/ethnicity, Veteran status, sexual orientation, or geography with mental illness on process of healthcare indicators | Low strength of evidence | Observational comparative effectiveness studies

Abbreviation: PTSD=posttraumatic stress disorder

Although several of the included studies were conducted in VA user populations, there is still a notable gap between the type and amount of relevant research that has been conducted in the VA system and the variety of analyses with large samples that are possible given the VA’s wealth of clinical and administrative data. With the VA’s national electronic medical record, single-payer system, and network of health services research centers, the VA is well-positioned to conduct the needed research.

## CONCLUSIONS

In this review, we found weak signals to support disparities in selected process of care indicators for those with mental illness compared to adults without mental illness; however, results were inconsistent, and beyond diabetes care, the existing literature was sparse. All identified studies used observational designs and were of at least fair quality (NOS score ≥5). For observational studies, the SOE is set initially at “low” and upgraded only for methodologically strong studies with large effects or a strong dose-response pattern, or decreased to “very low” for important risk of bias, inconsistent results, imprecise results, indirect evidence, or evidence of reporting bias. Since none of the outcomes met the upgrade criteria, the SOE for all outcomes are rated low or very low. While the majority of studies displayed negative associations between mental illness and quality indicators, only one meta-analysis—that of disparities in receiving cervical cancer screening—was statistically significant. Most meta-analyses displayed high heterogeneity in the summary estimates, likely due to small number of studies, differences in populations (eg, identification of those with current vs lifetime mental illness), and assessment of outcomes (eg, self-report vs claims data), and study design issues (eg, which covariates were used in adjusted analyses). We observed some qualitative differences in care patterns for studies conducted inside the VA healthcare system versus outside the VA healthcare system that may highlight areas for further research or quality improvement activities. Although several of the included studies were conducted in VA user populations, there are notable gaps in research that researchers with access to VA data may be well-positioned to address.