# RESULTS

In this section of the report, we describe the results of the literature search, followed by a synthesis of each preventive service (cancer screening, immunizations, smoking) and chronic disease state (diabetes, hypertension, ischemic heart disease) and finally, a meta-synthesis describing the volume of studies across all conditions.

## LITERATURE SEARCH

The flow of articles through the literature search and screening process is illustrated in Figure 2. A combined search of PubMed (n=1,927), Embase (n=1,599), PsycINFO (n=363), and The Cochrane Library (n=22) on the 6 conditions of interest yielded 3,911 citations from 1994 through February 2014. We supplemented the electronic searches with a manual search of the reference lists of systematic and nonsystematic reviews, as well as a set of key primary articles.20,21 which identified 53 more citations, for a total of 3,964 citations. After applying inclusion and exclusion criteria at the title-and-abstract level, 310 full-text articles were retrieved for further evaluation. Of these, 285 were excluded at the full-text screening stage, leaving 26 articles describing 23 unique primary studies for data abstraction.

Figure 2 Literature Flow Chart

* Results from PubMed (1,927), Embase (1,599), PsycINFO (363), The Cochrane Library (22), and manual searching (53)

** Companion articles provided additional details on methods and results for included studies.

The 23 included studies examined whether disparities in care exist for patients with mental health disorders regarding 3 preventive services—cancer screening (n=7), receipt of immunizations (n=3), and screening for tobacco use and referral for treatment (n=2)—and the management of 3 chronic diseases—type 2 diabetes mellitus (n=14), hypertension (n=2), and ischemic heart disease (n=1). Most studies used cross-sectional (n=11) or retrospective cohort (n=10) designs; 2 were prospective cohort studies. All studies used national (n=10), state (n=5), or local (n=8) databases. Approximately half of all included studies (n=12) studies were conducted within the VA healthcare system.

The mental health disorders examined were those of most interest to our stakeholders due to their prevalence in Veterans. The majority of studies described the subjects with mental health disorders versus those without mental health disorders separately (n=17). In the 23 included studies, the subjects with a mental health diagnosis had a median age of 58 years (range 42.2 to 67.0 years; not reported in 6 studies) and fell into 2 categories in terms of their sex distribution: those with 0 to 20% females (n=11) and those with 50% to 100% females (n=12), with a grand median of 48.7% female. A median of 58.3% (range 11.7 to 79.2) were white. Subjects without a mental health diagnosis had a median age of 58 years (range 46.9 to 68.5; not reported in six studies) and also fell into 2 categories in terms of their sex distribution: those with 0 to 14% female (n=10) and those with 35% to100% female (n=13), with a grand median of 46.0% female. A median of 62.0% (range 4.3% to 82.4%) were white. The studies that described subjects as a total population (n=6) did not differ to a large extent on age or sex distribution, but none of them reported race/ethnicity. Appendix D provides detailed study characteristics for each of the included studies. Appendix E provides the NOS quality scores for each study per domain.

## KEY QUESTION 1A Among adult patients, are there health disparities for those with mental illness compared to those without mental illness in receipt of appropriate preventive care services and indicated screenings?

### Cancer Screening

#### Key Points

- We identified one prospective cohort, 3 retrospective cohort, and 3 cross-sectional studies that addressed cancer screening among individuals with mental illness compared to those without mental illness. Total NOS scores ranged from 5 to 7, suggesting that most studies were of fair quality.
- While we had adequate studies of sufficient homogeneity to conduct 3 meta-analyses, all but one pooled analysis displayed high heterogeneity (I^2^ ≥75%).
- Meta-analysis of 3 studies demonstrated that women with a diagnosis of depression were significantly less likely to have cervical cancer screenings (OR 0.87; 95% CI, 0.77 to 0.98; I^2^=6.3%).
- Existing evidence suggests small to moderate disparities in cancer screening for people with mental illness. Nearly all studies displayed a similar pattern of a negative association between having a mental health diagnosis and receipt of cancer screenings; however, not all comparisons were statistically significant.
- The 3 studies that assessed cancer screening among VA users with and without mental illness displayed a similar pattern of negative associations. Results, however, were inconsistent. Two reported statistically significant disparities in receipt of cancer screenings, while one study reported no significant differences between those with and without mental health diagnoses.

#### Description of Included Studies

Seven studies22-24,34-37 met inclusion criteria and compared rates of cancer screening among those with and without mental illness. Table 2 summarizes the characteristics of these studies. We identified 4 cohort24,35-37 and 3 cross-sectional studies.22,23,34 Three studies23,24,37 were exclusively with VA user populations. Most studies (n=4) used national22,23,34 or multi-city36 data. The remaining 3 studies used state,37 regional,35 or single-center24 data.

Table 2 Characteristics Cancer Screening Studies

Article | Geographic Location; Data Source; Total N | Population: Age in Years; % Female; % White | Mental Health Diagnoses; Measurement | Study Design | Data Source | Outcomes
Druss, 2002^23^ | National VA Healthcare systems (general and specialty) N=113,495 | Age (mean [SD]): MI=60.8 (12.9) NMI=66 (11.5) % Female: MI=20.1 NMI=13.1 % White: MI=67.6 NMI=62.1 | Composite of mental health conditions: psychiatric disorders (excluding substance abuse) ICD-9 codes | Cross-sectional | EPRP chart review, 1998-1999; Patient Encounter, OP, and Patient Treatment files | Breast cancer screening; Cervical cancer screening; Colorectal cancer screening: FOBT, sigmoidoscopy, or colonoscopy
Druss, 2008^22^ | National National-level survey data N=30,081 | Age (mean [SD]): MI=42.2 (0.41) NMI=46.9 (0.18) % Female: MI=70 NMI=55 % White: MI=76 NMI=76 | Major depression Score ≥3 on CIDI-SF | Cross-sectional | NHIS, 1999 | Breast cancer screening; Cervical cancer screening; Colorectal cancer screening: FOBT
Egede, 2010^34^ (Companion: Egede, 2009^38^) | National Randomized survey N=16,754 | Age (category): MI: 18-34: 8.1% 35-49:28.3% 50-64:42.5% 65+:21.1% NMI: 18-34:4.6% 35-49:17.4% 50-64:38.4% 65+:39.6% % Female: MI=61.6 NMI=46.3 % White: MI=63 NMI: 62 | Major depression among those with diabetes PHQ-8 | Cross-sectional | BRFSS 2006 | Breast cancer screening; Cervical cancer screening; Colorectal cancer screening: FOBT, sigmoidoscopy, or colonoscopy
Kodl, 2010^24^ | Minneapolis, MN Facility-level VA Healthcare system N=855 | Age (mean [SD]): MI=59.4 (6.6) NMI=63.8 (7.6) % Female: MI=20.3 NMI=35.6 % White: MI=48 NMI=68.7 | PTSD Composite of mental health conditions: unipolar or bipolar depression, bipolar disorder, MDD, depressive disorders SMI composite: schizophrenia, delusional disorders, nonorganic psychoses ICD-9 codes | Retrospective cohort | Electronic medical record (1996-2006) | Colorectal cancer screening: FOBT, sigmoidoscopy, or colonoscopy
Lasser, 2003^35^ | Cambridge & Somerville, MA Local-level database from PC centers N=526 | Age range: 40 to 70 % Female=100 % White=52.1 | PTSD Composite of mental health Psychotic disorders Mood disorders (depressive disorders) PRIME-MD (modified) | Retrospective cohort | PRIME-MD records, 1998 to “present” (precise year/date not specified), from CHA administrative files | Breast CA screening
Pirraglia, 2004^36^ | Boston, MA; Chicago, IL; Detroit, MI; Los Angeles & Oakland, CA; Hudson County, NJ; Pittsburgh, PA Databases N=3,297 | Age (category): >50 years: (10.2%) % Female=100 % White=47 | Major depression (high ≥21) Depressive disorder (moderate 16-20) CES-D | Prospective cohort | SWAN longitudinal Cohort, 1996-1997 | Breast cancer screening; Cervical cancer screening
Yee, 2011^37^ | New Mexico State-level VA Healthcare system N=606 | Age (mean [SD]): MI=57.2 (5.1) NMI=57.7 (5.7) % Female=100 % White: MI=42 NMI=20 | Composite of mental health conditions: anxiety, depressed mood, dissociative symptoms, eating disorders, impulse control or somatoform disorders, manic symptoms, personality disorders, psychosis, and SUD ICD-9 codes | Retrospective cohort | NMVAHCS database (includes any clinic type), October 1, 2003 to September 30, 2006 | Breast cancer screening; Cervical cancer screening; Colorectal cancer screening: FOBT, sigmoidoscopy, or colonoscopy

Abbreviations: BRFSS=Behavioral Risk Factor Surveillance Survey; CHA=Cambridge Health Alliance; CIDI-SF=Composite International Diagnostic Interview-Short Form; EPRP=External Peer Review Program; FOBT=fecal occult blood test; ICD-9=International Classification of Diseases, 9th revision; N=number of participants; MI=mental illness; NHIS=National Health Interview Survey; NMI=no mental illness; NMVAHCS=New Mexico VA healthcare system; OP=outpatient; PC=primary care; PRIME-MD=Primary Care Evaluation of Mental Disorders; SUD=substance use disorder; SWAN=Study of Women’s Health Across the Nation

Four studies22,23,34,37 assessed screening for all 3 cancers of interest and included 161,236 patients. Demographically, the populations of these 4 studies varied, with the percentage of women ranging from 17% to 100% and the percentage of white participants ranging from 31% to 76%. One study35 addressed mammography only and included 526 women. Another36 addressed both breast and cervical cancer screening and included 3,297 women. One study with 855 participants24 addressed only colorectal cancer screening and included predominantly men (72%). All 3 of these studies24,35,36 enrolled around 50% white participants (47% to 58%). Three studies recruited participants with major depressive disorder,22,34,36 and 4 assessed composite groups with broad sets of mental health diagnoses.23,24,35,37

#### Synthesis of Findings: Cancer Screening

We classified studies and organized findings by outcome (eg, mammography, Pap test, colorectal cancer screening). We had adequate studies of sufficient homogeneity to perform 3 meta-analyses comparing cancer screening rates among populations with and without depressive disorders; however, all but one displayed high heterogeneity. We synthesized other findings qualitatively.

##### Breast Cancer Screening (Mammograms)

Six studies—3 cohorts35-37 and 3 cross-sectional22,23,34—addressed mammography. All of the studies reported on the proportion of participants who had received mammography in the past 2 or 3 years. Five studies specified minimum age for participants. One evaluated women 42 years or older,36 2 evaluated women 50 years or older,22,23 and one evaluated women 40 years and older and 50 years and older in separate groups.34 The other 2 studies did not specify an age range.35,37

We identified 4 studies—2 cohorts and 2 cross-sectional—that met criteria for a random-effects meta-analysis assessing mammography screening among individuals with depressive disorders compared to those without depression.22,34-36 The summary estimate, however, displayed high heterogeneity (I^2^=77.5%); therefore, it is not reported. All studies found negative relationships between receipt of mammography and depressive disorders (OR range: 0.48 to 0.92) and 3 of the 4 studies reported negative and significant difference in the odds of mammography (OR range: 0.48 to 0.82)22,34,35 (Figure 3).

Figure 3 Forest Plot of Meta-analysis for Mammography Screening Among Women With Depressive Disorders Relative to Women Without Depressive Disorders

Lasser et al35 also provided estimates for mammography use among women with PTSD and psychotic disorders compared to women without mental illness. Women with PTSD had a statistically significantly lower rate of mammograms compared to women without mental illness (37% vs 56%; chi-squared p=0.06), while women with psychotic disorders did not have significantly lower rates (67% vs 56%; chi-squared p=not statistically significant [NS]).

We identified 2 additional studies that provided estimates of mammography screening rates among Veteran women with broadly defined mental illness compared to those without mental illness.23,37 Results were mixed. One cross-sectional study used the 1999 VA External Peer Review Program (EPRP) chart review-based database and found significantly lowers odds of mammography among Veterans with mental illness (OR 0.78; 95% CI, 0.67 to 0.91; p<0.01).23 The second retrospective cohort study used the New Mexico VA healthcare system database and found no statistically significant difference in mammography screening among Veterans with and without diagnoses of mental illness (OR 0.79; 95% CI, 0.50 to 1.25).37

##### Cervical Cancer Screening

Five studies evaluated rates of cervical cancer screening via Pap test among women with and without mental illness.22,23,34,36,37 All 5 studies reported the completion of Pap tests over the past 1 to 3 years. Two studies specified that the participants were 65 years old or younger,22,23 and one specified that participants were 42 to 56 years old.36 The other studies specified only that participants were adults.34,37

We identified 3 studies—2 cross-sectional and one prospective cohort—that met criteria for a random-effects meta-analysis assessing Pap tests among women with depressive disorders compared to those without depression.22,34,36 Women with depressive disorders were significantly less likely to receive Pap smears (OR 0.87; 95% CI, 0.77 to 0.98), and the summary estimate displayed low heterogeneity (I^2^=6.3%) (Figure 4).

Figure 4 Forest Plot of Meta-analyses for Pap Testing Among Women With Depressive Disorders Relative to Women Without Depressive Disorders

Two additional studies provided estimates of cervical cancer screening rates among women with broadly defined mental illness compared to those without mental illness.23,37 One cross-sectional study23 addressed Pap smear screening in the VA as assessed through the 1999 VA EPRP chart review-based database and found significantly lower odds of Pap smear screening among female Veterans with mental illness (OR 0.87; 95% CI, 0.78 to 0.96; p<0.001). The second retrospective cohort study also addressed Pap smear screening among Veterans, but used state-level data from the New Mexico VA healthcare system database.37 This study did not find a significant difference in Pap smear screening among Veterans with and without diagnoses of mental illness; the estimate of effect was imprecise (OR 1.71; 95% CI, 0.91 to 3.21).

##### Colorectal Cancer Screening (FOBT, Sigmoidoscopy, or Colonoscopy)

Five studies addressed colorectal cancer screening disparities.22-24,34,37 Three used a composite outcome that included FOBT within the past year or flexible sigmoidoscopy within the past 5 years or colonoscopy within the past 10 years.23,24,37 One study assessed rates of FOBT, sigmoidoscopy, and colonoscopy separately.34 One study assessed only for FOBT within the past year.22

We identified 3 studies—2 cross-sectional and one retrospective cohort—that met criteria for a random-effects meta-analysis assessing colorectal cancer screening among individuals with depressive disorders compared to those without depression.22,24,34 the summary estimate, however, displayed high heterogeneity (I^2^=75.9%); therefore, it is not reported. All studies reported a negative association between depressive disorders and receipt of colorectal cancer screening (OR range: 0.43 to 0.90; median OR=0.85). Two of the 3 studies reported statistically significant findings (Figure 5).

Figure 5 Forest Plot of Meta-analyses for Colorectal Cancer Screening Among Individuals With Depressive Disorders Relative to Those Without Depressive Disorders

Three studies provided estimates of colorectal cancer screening rates among Veterans with broadly defined mental illness compared to those without mental illness.23,24,37 These studies used a composite outcome for colorectal cancer screening including FOBT, sigmoidoscopy, or colonoscopy. One cross-sectional study addressed colorectal cancer screening in the VA as assessed through the 1998/1999 VA EPRP chart review-based database.23 This study found a significantly lower odds of colorectal cancer screening among Veterans with mental illness (OR 0.95; 95% CI, 0.91 to 0.99; p<0.05). The second retrospective cohort study addressed colorectal cancer screening among Veteran using administrative claims data from the Minneapolis VA Medical Center (timeframe 1996 to 2006) and found that patients with any mental health diagnosis were less likely to receive colorectal cancer screenings (57% vs 47%; p<0.01).24 The third study, also a retrospective cohort, used state-level data from the New Mexico VA healthcare system database.37 This study did not find a significant difference in colorectal cancer screening among Veterans with and without diagnoses of mental illness (OR 0.85; 95% CI, 0.56 to 1.28).

Kodl et al24 also provided estimates for receipt of colorectal cancer screening for those with PTSD and psychotic disorders versus those without these diagnoses. There was a significant and negative association between a psychotic disorders diagnosis and receipt of colorectal cancer screening (β coefficient -0.90; p<0.001), but not for PTSD (β coefficient -0.37; p=0.19).

##### Composite measures of cancer screening

No studies reported on general cancer screening as a composite outcome.

#### Summary of Findings: Cancer Screening

We identified 7 studies that addressed cancer screening among individuals with mental illness compared to those without mental illness.22-24,34-37 Most studies (n=4) addressed all 3 types of cancer screening.22,23,34,37 We had adequate studies of sufficient homogeneity to conduct meta-analyses only for studies addressing disparities in breast, cervical, or colorectal cancer screening among those with depressive disorders compared to those without depression. Cervical cancer screening was the only area where the meta-analysis displayed low to moderate heterogeneity and showed significant differences in screening rates. Meta-analysis of 3 studies demonstrated that women with a diagnosis of depression were less likely to have cervical cancer screenings (OR 0.87; 95% CI, 0.77 to 0.98; I^2^=6.3%).

Existing evidence suggests small to moderate disparities in cancer screening for people with mental illness. Nearly all studies displayed a similar pattern of a negative association between having a mental health diagnosis and receipt of cancer screenings; however, several comparisons were not statically significant. The studies conducted that assessed the odds of breast, cervical, and colorectal cancer screening among VA users with and without mental illness displayed a similar pattern of negative associations. Results, however, were inconsistent. Two studies addressed all 3 cancers of interest among individuals with broadly defined mental illness compared to those without mental illness,23,37 and one assessed disparities in colorectal cancer screening only.24 A VA study using national data on 113,495 VA users23 reported significantly lower odds of mammography (OR 0.78; 95% CI, 0.67 to 0.91; p<0.01), Pap smears (OR 0.87; 95% CI, 0.78 to 0.96; p<0.001), and colorectal cancer screening (OR 0.95; 95% CI, 0.91 to 0.99; p<0.05) among Veterans with mental illness. Another VA study using state-level data on 606 Veterans in the New Mexico VA healthcare system database37 reported no significant difference in the odds of mammography (OR 0.79; 95% CI, 0.50 to1.25), Pap smears (OR 1.71; 95% CI, 0.91 to 3.21), or colorectal cancer screening (OR 0.85; 95% CI, 0.56 to 1.28) among Veterans with mental illness. The last VA study provided estimates for receipt of colorectal cancer screening for those with PTSD, psychotic disorders, depression, or any mental health diagnosis.24 There was a significant and negative association between mental health diagnosis and receipt of colorectal cancer screening for all groups except those with PTSD.

Of note, it is likely that differences in power drive the differences in statistically significant outcomes observed across these studies. An alternative hypothesis is that there are regional differences (eg, state-level variability) that are washed out in larger studies with national samples. The largest study23 included 113,495 participants recruited from a national sample of individuals with a diverse group of psychiatric illnesses and found significantly lower odds of cancer screening among those with mental illness in all 3 areas of interest: breast, cervical, and colorectal cancer. The second largest study22 included 30,081 participants recruited from a national sample of individuals with major depressive disorder and also found significant disparities in screening for all 3 cancers of interest. The 3 state-level studies had sample sizes ranging from 416 to 855 and reported mixed results. These studies may have been underpowered to detect the differences seen in the 2 larger studies. Alternatively, these studies may be assessing regional variations in cancer screening between those with and without mental illness.

#### Quality of Evidence for Cancer Screening Studies

Total NOS scores ranged from 5 to 7, suggesting that most studies were of fair quality, with 3 of the studies scoring a 5,^22,23,35^ one scoring a 6,^36^ and 3 scoring a 7^24,34,37^ (Figure 6). The included studies rated high on selection, with all studies receiving either a 3^22,23,34-36^ or a 4^24,37^ in this area. This indicates a high level of representativeness of the selected population and fidelity in ascertainment of the exposure of interest. There was significant variability in the area of comparability, with about half of the studies receiving a 2^22,34,36^ and half receiving a 0^23,24,35,37^ on this 2-point scale. This indicates variability in the adequacy of controls for potential confounders in the studies reviewed. There was also significant variability in the area of outcomes assessment and adequacy of follow-up windows, with scores of 0,^22^ 1,^36^ 2,^23,34,35^ and 3^24,37^ on this 3-point scale. Appendix E provides the scores for each study per domain.

Figure 6 Summary Newcastle-Ottawa Scale Quality Rating for Studies Reporting Cancer Outcomes

Abbreviations: NOS=Newcastle-Ottawa Scale; QA=quality assessment

### Immunizations

#### Key Points

- We identified 3 cross-sectional studies that compared vaccination use of those with mental illness and those without. Total quality scores ranged from 5 to 7 on the NOS, suggesting fair quality studies.
- Evidence for the existence of disparities in vaccination is limited. Overall, results were mixed, with no large disparities reported across studies.
- Three studies addressed influenza vaccination. Two studies found evidence to support disparities in receipt of influenza vaccinations, while another study found no significant differences in self-reported receipt of influenza vaccinations.
- Of the 2 studies that assessed ever receiving pneumococcal vaccinations, one medical chart-based study among VA users reported that patient with a psychiatric diagnosis had a lower probability of receiving a pneumococcal vaccine than patients without a psychiatric diagnosis. In contrast, another study reported that those with depression were no less likely to report receiving a pneumococcal vaccine than those without depression.

#### Description of Included Studies

Three studies met inclusion criteria and compared the use of age-appropriate immunizations (ie, influenza, pneumococcal) among those with and without mental illness.22,23,38 Table 3 summarizes the study characteristics of these studies. All studies were cross-sectional and used using national-level survey data. One study23 was conducted exclusively with VA user populations. Of the 160,330 patients included across the 3 studies, most were male, white, and aged 50 years or older. Two studies recruited patients with depressive disorders.22,38 The third study included a broad group of those with International Classification of Diseases, 9th revision (ICD-9) codes for psychiatric disorders, with and without a dual diagnosis of substance use disorder (SUD).23

Table 3 Characteristics of Immunization Studies

Article | Geographic Location; Data Source; Total N | Population: Age in Years; % Female; % White | | Mental Health Diagnoses; Measurement | Study Design | Data Source | Outcomes
Druss, 2002^23^ | National VA Healthcare systems (general and specialty) N=113,495 | Age (mean [SD]): MI=60.8 (12.9) NMI=66 (11.5) | | Composite of mental health conditions: psychiatric disorders (excluding substance abuse) ICD-9 codes | Cross-sectional | EPRP chart review, 1998-1999; Patient Encounter, OP, and Patient Treatment files | Influenza vaccine past year; Pneumococcal vaccine ever
Druss, 2002^23^ | National VA Healthcare systems (general and specialty) N=113,495 | % Female: | MI=20.1 NMI=13.1 | Composite of mental health conditions: psychiatric disorders (excluding substance abuse) ICD-9 codes | Cross-sectional | EPRP chart review, 1998-1999; Patient Encounter, OP, and Patient Treatment files | Influenza vaccine past year; Pneumococcal vaccine ever
Druss, 2002^23^ | National VA Healthcare systems (general and specialty) N=113,495 | % White: | MI=67.6 NMI=62.1 | Composite of mental health conditions: psychiatric disorders (excluding substance abuse) ICD-9 codes | Cross-sectional | EPRP chart review, 1998-1999; Patient Encounter, OP, and Patient Treatment files | Influenza vaccine past year; Pneumococcal vaccine ever
Druss, 2008^22^ | National National-level survey data N=30,081 | Age (mean [SD]): MI=42.2 (0.41) NMI=46.9 (0.18) | | Major depression Score ≥3 on CIDI-SF | Cross-sectional | NHIS, 1999 | Influenza vaccination in past year
Druss, 2008^22^ | National National-level survey data N=30,081 | % Female: | MI=70 NMI=55 | Major depression Score ≥3 on CIDI-SF | Cross-sectional | NHIS, 1999 | Influenza vaccination in past year
Druss, 2008^22^ | National National-level survey data N=30,081 | % White: | MI=76 NMI=76 | Major depression Score ≥3 on CIDI-SF | Cross-sectional | NHIS, 1999 | Influenza vaccination in past year
Egede, 2009)38 (Companion to: Egede, 2010^34^) | National Randomized survey n=16,754 | Age (category): | | Major depression among those with diabetes PHQ-8 | Cross-sectional | BRFSS 2006 | Flu shot in past year; Pneumonia vaccine ever
Egede, 2009)38 (Companion to: Egede, 2010^34^) | National Randomized survey n=16,754 | MI: | 18-34: 8.1% 35-49: 28.3% 50-64: 42.5% 65+: 21.1% | Major depression among those with diabetes PHQ-8 | Cross-sectional | BRFSS 2006 | Flu shot in past year; Pneumonia vaccine ever
Egede, 2009)38 (Companion to: Egede, 2010^34^) | National Randomized survey n=16,754 | NMI: | 18-34: 4.6% 35-49: 17.4% 50-64: 38.4% 65+: 39.6% | Major depression among those with diabetes PHQ-8 | Cross-sectional | BRFSS 2006 | Flu shot in past year; Pneumonia vaccine ever
Egede, 2009)38 (Companion to: Egede, 2010^34^) | National Randomized survey n=16,754 | % Female: | MI=61.6 NMI=46.3 | Major depression among those with diabetes PHQ-8 | Cross-sectional | BRFSS 2006 | Flu shot in past year; Pneumonia vaccine ever
Egede, 2009)38 (Companion to: Egede, 2010^34^) | National Randomized survey n=16,754 | % White: | MI=63 NMI: 62 | Major depression among those with diabetes PHQ-8 | Cross-sectional | BRFSS 2006 | Flu shot in past year; Pneumonia vaccine ever

Abbreviations: BRFSS=Behavioral Risk Factor Surveillance Survey; CIDI-SF=Composite International Diagnostic Interview-Short Form; EPRP=External Peer Review Program; ICD-9=International Classification of Diseases, 9^th^ revision; MI=mental illness; N=number of participants; NHIS=national Health Interview Survey; NMI=no mental illness; OP=outpatient; PHQ-8= Patient Health Questionnaire-8; SD=standard deviation; VA=Veterans Affairs

#### Synthesis of Findings: Immunization

We classified studies and organized findings by outcome (eg, influenza vaccination, pneumococcal vaccination). We did not have adequate studies of sufficient homogeneity to perform meta-analyses; therefore, we synthesize finding qualitatively.

##### Influenza Vaccination

Three studies compared likelihood of influenza vaccination between those with mental illness and those without. One large cross-sectional, medical chart-based study23 (n=91,806) compared VA users who were either older than age 65 or in high-risk groups with psychiatric disorders versus Veterans without psychiatric disorders for the outcome of receiving an influenza vaccination within the past year. Presence of a psychiatric diagnosis as measured by ICD-9 codes predicted a significantly lower probability of receiving an influenza vaccine than no psychiatric diagnosis (OR 0.90; 95% CI, 0.87 to 0.94).

Two studies assessed the receipt of influenza vaccinations in the past year among those with depressive disorders. The first22 used data from the 1999 National Health Interview Study (NHIS) and found that among person aged 50 and older, those with depression were significantly more likely than those without depression to report not receiving an influenza vaccination in the past year (OR 1.24; 95% CI, 1.18 to 1.30). Depression was assessed via the Composite International Diagnostic Interview-Short Form (CIDI-SF). The second study38 used data from the 2006 Behavioral Risk Factor Surveillance Survey (BRFSS) and found no significant difference in influenza vaccination among adults 18 and older with major depression as assessed via the Patient Health Questionnaire-9 (PHQ-9) compared to those without depression (OR 0.85; 95% CI, 0.67 to 1.09). Of note, the BRFSS study did not control for other mental health diagnoses in the comparisons group; thus the comparisons group could have contained individuals with other mental illnesses.

##### Pneumococcal Vaccination

Two studies compared the likelihood of lifetime pneumococcal vaccination in those with mental illness versus those without. One VA medical chart-based study23 compared Veterans either older than age 65 or in high-risk groups with psychiatric disorders versus Veterans without psychiatric disorders for the outcome of ever receiving a pneumococcal vaccination. This study found that presence of a psychiatric diagnosis predicted a significantly lower probability of receiving a pneumococcal vaccine than no psychiatric diagnosis (OR 0.95; 95% CI, 0.93 to 0.96). A second study used data from the 1999 NHIS22 and found no significant difference in patient-reported lifetime pneumococcal vaccination among adults 18 and older with major depression as assessed via the PHQ-9 compared to those without depression (OR 1.03; 95% CI, 0.88 to 1.30). Again, this study did not report controlling for other mental illnesses in the comparisons group.

#### Summary of Findings: Immunization

We identified 3 cross-sectional studies that compared vaccination use of those with mental illness and those without. All 3 studies addressed influenza vaccination, while 2 studies also addressed pneumococcal vaccination. Evidence for the existence of disparities in vaccination is mixed. The 2 studies of older adult and high-risk subpopulations22,23 found evidence to support disparities in receipt of influenza vaccinations, while another study found no significant differences in self-reported receipt of influenza vaccinations38 among a general population of adults. Of the 2 studies that assessed ever receiving pneumococcal vaccinations, one medical chart-based study among VA users reported that patients with a psychiatric diagnosis had a lower probability of receiving a pneumococcal vaccine than patients without a psychiatric diagnosis.23 In contrast, another study conducted outside the VA reported that those with depression were no less likely to report receiving a pneumococcal vaccine than those without depression, but this study did not control of the presence of other mental illnesses in the comparator.22

#### Quality of Evidence for Immunization Studies

Total quality scores ranged from 5 to 7 on the NOS, with 2 of the studies scoring a 5^22,23^ and one scoring a 7.^38^ Appendix E provides the scores for each study per domain. All 3 studies were rated as representative of the average person with mental illness from the community; however, 2 studies22,38 ascertained depression status by self-report via telephone interviews, while the other study23 used ICD-9 codes from VA medical records. Of note, 2 studies22,38 did not report whether those with and without depression had other comorbid mental illnesses. Two studies had at least adequate control of confounding variables in the design or analysis,22,38 while the other study23 did not control for the minimal confounding variables of age, sex, race/ethnicity, and socioeconomic status. One study23 used record linkage to determine the outcomes of interest, and the other 2^22,38^ used self-report measures, which may be subject to greater bias than clinical records. The timeframe utilized was adequate for observing the outcomes in 2 studies,23,38 but may have been inadequate in the third.22 However, all 3 studies were of cross-sectional design; therefore we cannot demonstrate that the outcome of interest was not present at the start of the study.

### Screening and Referral for Tobacco Use

#### Key Points

- There is limited comparative evidence to describe disparities in tobacco use process of care indicators between those with mental illness and those without mental illness. We identified only 2 comparative studies that assessed screening for tobacco use and referral for smoking cessation treatment; no identified study directly reported on prescriptions for smoking cessation pharmacotherapy. Both studies were conducted with VA users and received total NOS scores of 5, suggesting studies of fair quality.
- A single cross-sectional study suggests that those with mental illness are more likely to be screened for tobacco use and referred for counseling than those without mental illness.
- One cross-sectional study suggests that smokers with PTSD and depressive disorders may be more likely to receive a physician’s recommendation for smoking cessation medications than those without mental illness, while smokers with schizophrenia may be less likely to receive advice to quit from physicians. No differences were found between smokers with a diagnosis of bipolar disorder and those without a mental health diagnosis for receipt of smoking cessation services.

#### Description of Included Studies

Two cross-sectional studies met inclusion criteria and compared screening for tobacco use, referrals to smoking cessation treatments, and prescriptions for smoking cessation pharmacotherapy among those with and without mental illness.23,39 Table 4 summarizes the study characteristics of these studies. Both studies were conducted exclusively with VA user populations and used data from nationwide surveys conducted by the Veterans Health Administration (VHA), the 1999 VHA EPRP23 and the 2007 VHA Outpatient Survey of Healthcare Experiences of Patients (SHEP).39 Of the 337,688 patients across the 2 studies, most were male, white, and over 60 years of age. One study included patients with schizophrenia, bipolar disorder, depressive disorder, and PTSD, determined by ICD-9 codes.39 The other study included a broad group of those with ICD-9 codes for psychiatric disorders, with and without a dual diagnoses of SUD.23

Table 4 Characteristics of Tobacco Screening and Referral Studies

Article | Geographic Location; Data Source; Total N | Population: Age in Years; % Female; % White | Mental Health Diagnoses; Measurement | Study Design | Data Source | Outcomes
Druss, 2002^23^ | National VA Healthcare systems (general and specialty) N=113,495 | Age (mean [SD]): MI=60.8 (12.9) NMI=66 (11.5) % Female: MI=20.1 NMI=13.1 % White: MI=67.6 NMI=62.1 | Composite of mental health conditions: psychiatric disorders (excluding substance abuse) ICD-9 codes | Cross-sectional | EPRP chart review, 1998-1999; Patient Encounter, OP, and Patient Treatment files | Proportion screened for tobacco use; Proportion referred for smoking cessation treatments
Duffy, 2012^39^ | National National-level VHA outpatient survey N=224,193 | Age (category): <45: 3.4% 45-64: 37.4% ≥65: 59.2% % Female: 3.5 % White: 83.1 | Schizophrenia Bipolar disorder Depressive disorder PTSD ICD-9 codes | Cross-sectional | VHA Outpatient SHEP (fiscal year 2007) | Proportion prescribed tobacco cessation pharmacotherapy

Abbreviations: EPRP=External Peer Review Program; ICD-9=International Classification of Diseases, 9^th^ revision; MI=mental illness; N=number of participants; NHIS=National Health Interview Survey; NMI=no mental illness; OP=outpatient; PTSD= posttraumatic stress disorder; SD=standard deviation; SHEP=Survey of Healthcare Experiences of Patients; VA=Veterans Affairs; VHA= Veterans Health Administration

#### Synthesis of Findings: Tobacco

We classified studies and organized findings by outcome (eg, screening for tobacco use). We did not have adequate studies to perform meta-analyses; therefore, we synthesize findings qualitatively. While screening for tobacco use, referral for smoking cessation treatment, and prescribed tobacco-cessation therapies were outcomes of interest, no identified study reported on outcomes for prescribed tobacco-cessation therapies. However, one study39 reported 3 related outcomes: physician advice to quit, recommendations for medications, and physician discussions of quitting methods.

##### Screening for Tobacco Use

One large, cross-sectional, medical chart-based study23 compared the proportion of individuals with psychiatric disorders versus those without psychiatric disorders receiving screening for smoking or other tobacco use within the last year (n=113,505). This study reported that presence of a psychiatric diagnosis (without co-occurring SUD) predicted a significantly higher probability of tobacco screening than no psychiatric diagnosis (OR 1.17; 95% CI, 1.08 to 1.27).

##### Referred for Smoking Cessation Treatment

One study23 compared the proportion of smokers with psychiatric disorders versus smokers without psychiatric disorders receiving at least one documented counseling session or referral to a tobacco cessation program. Smokers with psychiatric disorders were significantly more likely to be referred to tobacco cessation programs than those without (OR 1.1; 95% CI, 1.00 to 1.20; p<0.05).

Another study39 reported 2 outcomes related to referrals for smoking cessation treatment: 1) physician advice to quit smoking, and 2) physician discussions of quitting methods during clinic visits. This study was a secondary analysis of patient-reported outcomes from the VA SHEP study linked with VA administrative data on diagnosis and sociodemographic characteristics of the respondents (n=224,193). Separate estimates were provided for smokers with bipolar disorder, depressive disorders, PTSD, and schizophrenia diagnoses compared to current smokers without a mental health diagnosis. Smokers with ICD-9 codes for schizophrenia were significantly less likely to report receiving a physician’s advice to quit than smokers with no mental disorder diagnoses (OR 0.69; 95% CI, 0.58 to 0.81). The study found no significant differences between smokers with no mental health disorder diagnosis and smokers with ICD-9 codes for bipolar disorder (OR 0.9; 95% CI, 0.76 to 1.06), depressive disorders (OR 1.04; 95% CI, 0.96 to 1.13), or PTSD (OR 1.09; 95% CI, 0.99 to 1.19). This study also compared rates of whether a physician had discussed quitting methods and found no significant differences between smokers with no mental health disorder diagnosis and smokers with bipolar disorder (OR 0.97; 95% CI, 0.86 to 1.1), depressive disorders (OR 1.05; 95% CI, 0.99 to 1.12), or schizophrenia (OR 1.00; 95% CI, 0.88 to 1.15). However, smokers with PTSD were significantly more likely to have a physician discuss quitting methods with them than smokers with no mental health disorder diagnosis (OR 1.09; 95% CI, 1.02 to 1.17).

##### Prescribed Tobacco-cessation Pharmacotherapy

Though no study directly reported physician prescribed tobacco-cessation pharmacotherapy, one study39 reported physician recommended medication for smoking cessation during ≥1 visits in a year. This study compared patient-reported rates of physician recommendations of smoking cessation medications among current smokers with a mental health diagnosis (ie, bipolar disorder, depressive disorders, PTSD, schizophrenia) and those without any mental health diagnosis. The study found no significant differences between smokers with no mental health disorder and smokers with bipolar disorder (OR 1.01; 95% CI, 0.88 to 1.14) or schizophrenia (OR 0.92; 95% CI, 0.8 to 1.05). However, smokers with depressive disorders (OR 1.07; 95% CI, 1.01 to 1.14) and PTSD (OR 1.14; 95% CI, 1.06 to 1.23) were significantly more likely report that a physician recommended medication for smoking cessation than patients without a mental health diagnosis.

#### Summary of Findings: Tobacco

Overall, there is limited comparative evidence to describe disparities in tobacco use process of care indicators between those with mental illness and those without mental illness. We identified only 2 comparative studies that assessed screening for tobacco use and referral for smoking cessation treatment; neither reported on prescriptions for smoking cessation pharmacotherapy. Both studies were conducted with VA users. One used self-report of receipt of smoking cessation services and reported results separately for the following groups: bipolar disorder, depressive disorders, PTSD, and schizophrenia.39 The other study used data obtained from medical chart reviews23 and compared individuals with any psychiatric diagnosis to individuals without a psychiatric diagnosis. The available evidence suggests those with mental illness are more likely to be screened for tobacco use and referred for counseling than those without mental illness. This result is based on a single cross-sectional study. One cross-sectional study suggests that smokers with PTSD and depressive disorders are more likely to receive a physician’s recommendation for smoking cessation medications than those without mental illness; smokers with PTSD were also more likely to report that a physician had discussed quitting methods with them. Smokers with schizophrenia reported they may be less likely to receive advice to quit from physicians compared to smokers without a mental health diagnosis; however, no significant differences were found for having a physician discuss quitting methods or having a physician recommend medication for smoking cessation. No differences were found between smokers with a diagnosis of bipolar disorder and those without a mental health diagnosis for receipt of smoking cessation services.

#### Quality of Evidence for Tobacco Use Studies

Both studies received a total score of 5 points on the NOS, suggesting fair quality studies (see Appendix E for details). Both studies were strongly representative, with appropriate non-exposed cohorts. Each study utilized clinical records to ascertain mental health status. Each study was of cross-sectional design; therefore we cannot demonstrate that the outcome of interest was not present at the start of the study. Only one study23 had adequate control of confounding variables in the analysis. The same study23 used record linkage to determine the outcomes of interest, while the other39 used self-report measures, which may be subject to greater bias than clinical records. The timeframe utilized was adequate for observing the outcomes in one study,23 but may have been inadequate in the other.39

## KEY QUESTION 1B Among adult patients, are there health disparities for those with mental illness compared to those without mental illness in management of chronic conditions?

### Diabetes Care

#### Key Points

- We identified 14 studies that met inclusion criteria and compared diabetes process of care outcomes among those with mental illness and those without mental illness. While several studies addressed depressive disorders, SMI, or composite groups of diabetic patients with mental illness, only one study assessed the impact of PTSD on diabetes quality of care indicators. Studies were of fair (n=11) to high (n=3) quality (NOS scores ≥5); however, most (n=10) did not adequately control for key potential confounders.
- We had adequate studies of sufficient homogeneity conduct 8 meta-analyses; however, all but one pooled analysis displayed high heterogeneity (I^2^ ≥75%).
- Meta-analysis of 3 studies demonstrated that people with a diagnosis of depression were no less likely than those without such diagnosis to have eye exams (OR 0.89; 95% CI, 0.56 to 1.41; I^2^=62.2%).
- For most outcomes, results were inconsistent and suggest small to modest disparities in diabetes care for people with mental illness.
- We observed some qualitative differences in care patterns for studies conducted inside the VA healthcare system versus outside the VA healthcare system.
  ○ For composite indicators of diabetes care, the one study conducted outside the VA reported a significant and negative association, while 2 studies conducted with VA users reported mixed results.
  ○ For patients with SMI, we observed a positive trend of more HbA1c monitoring for VA users, while results were inconsistent in the non-VA study.
  ○ VA users with a diagnosis of SMI were statistically significantly less likely to get eye exams. In contrast, the 2 studies conducted outside the VA displayed positive trend effects, but only one estimate was statistically significant.
  ○ This trend was reversed for adequacy of LDL-C control among patients with SMI. The VA studies demonstrated no significant differences between VA users with and without SMI. Yet, the one study that provided comparative estimates outside the VA reported significant and negative effects of SMI on achieving adequate LDL-C control.
  ○ Patterns for receipt of diabetic foot exams were similar inside and outside the VA; patients with mental illnesses were less likely to received foot exams compared to those without mental illness, but estimates were only significant for those patients seeking care inside the VA.

#### Description of Included Studies

Fourteen studies described in 16 papers met inclusion criteria and compared process of care outcomes (eg, HbA1c testing) among those with and without mental illness.38,40-54 Table 5 summarizes the study characteristics of these studies. All studies were relatively recent and published in a 10-year timeframe (2002 to 2012). We identified one prospective cohort, 6 retrospective cohort, 7 cross-sectional, and no case-control studies. Seven studies were conducted exclusively with VA user populations.41,44,45,47-49,51 Only 3 studies38,49,52 used patient interviews as part of the data sources; all other studies used medical or administrative records reviews. The 14 included studies encompassed 1,236,048 subjects, and sample sizes ranged considerably (from 124 to 657,628). Most subjects were white; however, 4 studies45,47,50,52 did not report race/ethnicity data. While almost half (45%) of the subjects were female, 8 studies were comprised of predominantly male samples. Seven studies provided estimates of effects between those without mental illness and groups comprised of a broad set of mental health diagnoses. Six studies provided estimates of effects for people with SMI.41,42,45,46,48,50 Five studies provided effect estimates among people with depressive disorders,38,45,47,50,52 and only one study provided separate effect estimates for people with PTSD.47

Table 5 Characteristics of Diabetes Studies

Article | Geographic Location; Data Source; Total N | Population: Age in Years; % Female; % White | Mental Health Diagnoses; Measurement | Study Design | Data Source | Outcomes
Desai, 2002^51^ | National VA healthcare system databases N=36,528 | Age (mean [SD]): MI=62.2 (12.0) NMI=65.9 (10.6) % Female: MI=18.9 NMI=11.1 % White: MI=67.9 NMI=61.2 | Composite of mental health conditions: psychiatric disorders (excluding SUD and dual diagnosis) ICD-9 codes | Retrospective cohort | VA computerized medical records: 1999 VA EPRP; Patient encounter files; Patient treatment files (January 1998 to December 1999) | HbA1c testing; Diabetic foot exam; Eye exam
Druss, 2012^40^ | National National-level database N=657,628 | Age (mean [SD]): MI=48.2 (0.4) NMI:=47.7 (0.6) % Female: MI=63.7 NMI=68.2 % White: MI=56.8 NMI=51.7 | Composite of mental health conditions: any mental health diagnosis excluding dementia/delirium ICD-9 codes | Retrospective cohort | Medicaid eligibility, service utilization, and payment database (2003-2004) | HbA1c testing; Eye exam; Nephropathy screening; At least 2 HEDIS quality indicators completed in a year
Egede, 2009^38^ Companion to: Egede, 2010^34^ | National Randomized survey N=16,754 | Age (category): MI: 18-34: 8.1% 35-49: 28.3% 50-64: 42.5% 65+: 21.1% NMI: 18-34: 4.6% 35-49: 17.4% 50-64: 38.4% 65+: 39.6% % Female: MI=61.6 NMI=46.3 % White: MI=63 NMI: 62 | Major depression among those with diabetes PHQ-8 | Cross-sectional | BRFSS 2006 | HbA1c testing; Diabetic foot exam; Eye exam
Frayne, 2005^49^ | National VA databases and survey N=313,586 | Age (category; n): MI: <55: 28,339 55-64: 16,051 65-74: 20,429 ≥75: 11,981 NMI: <55: 39,780 55-64: 47,357 65-74: 94,241 ≥75: 55,645 % Female: MI=3.3 NMI=1.8 % White: MI=73.4 NMI=74.5 | Composite of mental health conditions: depressed mood, anxiety, psychosis, manic symptoms, SUD, personality disorders, dissociative symptoms, somatoform symptoms, impulse control disorders, eating disorders ICD-9 codes | Cross-sectional | 6 sources (October 1997-September 1999): DEpiC; Medicare claims; VA National Patient Care Database; VHA Health Care Analysis Information Group (lab data); VHA Pharmacy Database; 1999 Large Health Survey of Veteran Enrollees | No HbA1c testing; No eye exam; LDL-C not at goal; Composite diabetes outcome: no monitoring for diabetes (no HbA1c test done, no LDL-C-test done, and no eye exam done)
Green, 2010^43^ | Atlanta, GA Facility-level database N=8,817 | Age (mean [SD]): MI=49.4 (10.2) NMI=55.6 (11.8) % Female: MI=61.4 NMI=64.3 % White: MI=11.7 NMI=4.3 | Schizophrenia Mood disorders ICD-9 codes | Retrospective cohort | ER, urgent care, and PC records (OP), 2004-2005, from urban, public hospital | HbA1c testing; Eye exam; Nephropathy screening
Jones, 2004^50^ | Iowa State-level population-based database N=26,020 | Age (mean [SD]): MI=47.1 (9.4) NMI=48.4 (10.2) % Female: MI=50.2 NMI=46.0 % White: NR | Mood disorders Psychotic disorders ICD-9 codes | Retrospective cohort | Administrative claims data from BCBS of Iowa (January 1996 to December 2001) | HbA1c testing; Eye exam; Nephropathy screening
Kilbourne, 2008^45^ (Companion: Morden, 2010^53^) | National VA healthcare system registries and databases N=10,943 | Age: 66.3 (11.) %Female Total=2.6 %White=NR | Composite SMI: schizophrenia, bipolar disorder, other psychosis Depression: unipolar depression, depressive disorders ICD-9 codes | Cross-sectional | VA National Registries for (1) Psychosis; and (2) Depression; EPRP national quality of care databases, fiscal year 2005 | BP under control; LDL-C at goal; Diabetic foot exam; Eye exam; HbA1c testing not received
Krein, 2006^48^ | National VA healthcare system registries N=36,546 | Age (mean [SD]): Total=58 (12) % Female: MI=4.0 NMI=: 14.0 % White: MI=64.0 NMI=69.0 | Composite SMI: schizophrenia, schizoaffective disorder, bipolar disorder, other nonorganic psychoses, paranoid states, affective psychoses ICD-9-CM codes | Cross-sectional | VA National Psychosis Registry & Healthcare Analysis and Information Group/QUERI-DM (diabetes registry), October 1997 to September 1998 | HbA1c testing; LDL-C at goal
Leung, 2011^42^ | Massachusetts State-level database N=10,6174 | Average age range: 52 to 65 yr % Female: MI=64.0 NMI=68.2 % White: MI=79.2 NMI=82.4 | Schizophrenia Bipolar disorder Depression/ anxiety Other MI ICD-9 codes | Cross-sectional | Massachusetts Medicaid & Medicare, 2004-2005 | HbA1c testing; Eye exam; Nephropathy screening
Lin, 2004^52^ | Seattle, WA HMO member survey N=4,385 | Age (mean [SD]): Total=63.3 (13.4) % Female=48.7 % White=NR | Major depression Depressive disorders PHQ-9 | Prospective cohort | GHC diabetes registry, 2001-2003 | No HbA1c testing; No eye exam; No nephropathy screening within past year among patients not taking ACEI
Nelson, 2011^41^ | Kansas City, KS Facility-level VAMC database N=124 | Age (mean [SD]): MI=57.9 (7.0) NMI=57.9 (2.2) % Female=0 % White: MI=35.5 NMI=69.5 | Composite SMI: schizophrenia, schizoaffective disorder, and psychosis NOS) ICD-9 codes | Cross-sectional | Computerized patient record system (CPRS) for 2008 | LDL-C at goal
Taveira, 2008^44^ (Companion: Cohen, 2010^54^) | Providence, RI VAMC facility-level database N=297 | Age (mean [SD]): MI=59.9 (9.4) NMI=68.5 (9.3) % Female: MI=4.1 NMI=1.1 % White: MI=49.6 NMI=39.8 | Schizophrenia Mood disorders (including depression and bipolar disorder) Depressive disorder Anxiety Dissociative and somatoform disorders PTSD ICD-9 codes | Cross-sectional | VAMC electronic medical records from CRRC, January 2001-January 2002 | Composite diabetes outcome: achieve at goal levels for at least 2 of these 3 values: SBP, LDL-C, or HbA1c
Trief, 2006^47^ | New York (state) VA Healthcare Network Upstate New York facility-level database N=14,438 | Average age range: MI: 59.6 to 64.3 NMI: 69.5 % Female: 0 %White: NR | PTSD with depression PTSD without depression Depression without PTSD ICD-9 codes | Retrospective cohort | Veterans Health Information Systems and Technology Architecture (VistA) for PC visits (July 1, 2003 to October 4, 2004) | LDL-C at goal
Weiss, 2006^46^ | Boston, MA 5 internal medicine practices N=3,808 | Age (mean [SD]): MI=62 (15) NMI=65 (13) % Female: MI=57.9 NMI=48.6 % White: MI=72.0 NMI=71.2 | Schizophrenia and other psychotic disorders ICD-9 codes | Cross-sectional | Review of charts or electronic medical records (January 1, 2000 to July 31, 2003) | Proportion with hyperlipidemia prescribed a statin; LDL-C at goal; BP under control

Abbreviations: ACEI=angiotensin converting enzyme inhibitor; BCBS=Blue Cross Blue Shield; BP=blood pressure; BRFSS=Behavioral Risk Factor Surveillance Survey; DEpiC=Diabetes Epidemiology Cohort; DM=diabetes mellitus; EPRP=External Peer Review Program; ER=emergency room; GHC=Group Health Cooperative; GIM=general internal medicine; HbA1c=glycated hemoglobin; HEDIS=Healthcare Effectiveness Data and Information Set; HMO=health maintenance organization; ICD-9=International Classification of Diseases, 9^th^ revision; IP=inpatient; LDL-C=low-density lipoprotein cholesterol; MI=mentally ill; N=number of participants; NMI=no mental illness; OP=outpatient; PC=primary care; PHQ-9=Patient Health Questionnaire-9; PTSD=posttraumatic stress disorder; QUERI-DM=Diabetes Mellitus Quality Enhancement Research Initiative; SBP=systolic blood pressure; SD=standard deviation; SMI=serious mental illness, usually schizophrenia, schizoaffective disorder, and bipolar disorder; SUD=substance use disorder; VA=Veterans Affairs; VAMC=Veteran Affairs Medical Center

#### Synthesis of Findings: Diabetes Care

We classified studies and organized findings by outcome. We had adequate studies of sufficient homogeneity to perform 8 meta-analyses for selected process of care indicators; most of these analyses yielded high heterogeneity. We synthesized other finding qualitatively, grouped by diabetes process of care indicator and then by mental health condition assessed.

##### Composite Measure of Comprehensive Diabetes Care

Three studies reported on a composite measure of care for patients with diabetes and compared those with and without mental illness.40,44,49 One study created a composite measure that included the proportion of subjects who had not received any of 3 key quality indicators (ie, no HbA1c test done, no LDL-C test done, and no eye examination performed) in the past year.49 Another study created a composite measure based on achievement of target levels for at least 2 of the 3 goal values for systolic BP, LDL-C, or HbA1c.44 The last study developed a composite measure based on obtaining 2 or more of the Healthcare Effectiveness Data Information Set (HEDIS) diabetes performance measures (ie, HbA1c testing, LDL-C screening, eye examinations, treatment for nephropathy).40 All 3 of these studies were conducted with medical or administrative record reviews and identified subjects with mental illness based on ICD-9 codes for a broad range of diagnoses. Two were conducted among VA users.44,49 These studies met criteria for a random-effects meta-analysis that assessed the impact of mental illness on composite indicators of diabetes care, but the summary estimate displayed high heterogeneity (I^2^=95.8%); therefore, it is not reported. Results were mixed, with effects ranging from negative and statistically significant (OR 0.72; 95% CI, 0.70 to 0.75) to positive and not statistically significant (OR 1.34; 95% CI, 0.84 to 2.14) (Figure 7). Of note, the patients in Taveira et al44 were drawn from a group of VA patients who had just completed a pharmacist-led cardiovascular risk reduction clinic and likely contributed to the high heterogeneity in the summary estimate.

Figure 7 Forest Plot of Meta-analyses of the Association of Mental Illness and Composite Indicators of Diabetes Care

##### HbA1c Testing

Ten studies assessed the association of mental health status on the receipt of HbA1c testing among patients with diabetes.38,40,42,43,45,48-52 Four of these studies were conducted with VA users.45,48,49,51 Four studies provided estimates for those with depressive disorders, 4 for those with SMI, and 5 for those diagnosed with any of a broad range of mental illnesses. We were able to perform 3 meta-analyses for the receipt of HbA1c comparing those without a mental health diagnosis to those with depressives disorders, SMI, or a group composite group of a broad set of mental health diagnoses. All 3 summary estimates, however, displayed high heterogeneity. Thus, we synthesize results qualitatively.

Four studies reported on the receipt of HbA1c testing among patients with diabetes and compared those with and without a diagnosis of depressive disorders.38,45,50,52 Three of these studies met criteria for a random-effects meta-analysis assessing the impact of mental illness on receipt of HbA1c testing, but the summary estimate displayed high heterogeneity (I^2^=82.3%); therefore, it is not reported. Results were mixed, with effects ranging from negative and statistically significant (OR 0.53; 95% CI, 0.35 to 0.79) to positive and not statistically significant (OR 1.11; 95% CI, 0.95 to 1.30) (Figure 8). One other study provided estimates of effects but provided only a hazard ratio (HR);50 this study, conducted with claims data from Blue Cross Blue Shield of Iowa, also did not find a statistically significant effect of depressive disorders on receipt of HbA1c testing (HR 0.97; 99.9% CI, 0.90 to 1.06).

Figure 8 Forest Plot of Meta-analyses of the Association of Depressive Disorders and Receipt of HbA1c Testing Among Patients with Diabetes

Four studies assessed the impact of SMI on the receipt of HbA1c testing among patients with diabetes, and 3 of these were amenable to pooled analyses in a random-effects meta-analysis.42,45,48 but the summary estimate displayed very high heterogeneity (I^2^=92.4%); therefore, it is not reported. All studies displayed a positive association between presence of an SMI diagnosis and receipt of HbA1c (OR range: 1.02 to 1.51; median OR=1.17), and 2 of these estimates were statistically significant42,48 (Figure 9). One other study provided estimates of effects but provided only an HR50; this study, conducted with claims data from Blue Cross Blue Shield of Iowa, reported a negative but statistically insignificant association of SMI and receipt of HbA1c testing (HR 0.79; 99.9% CI, 0.54 to 1.15).

Figure 9 Forest Plot of the Association of SMI and Receipt of HbA1c Testing Among Patients with Diabetes

Five studies assessed the association of broadly defined mental illness on receipt of HbA1c testing. All met criteria for a random-effects meta-analysis, but the summary estimate displayed very high heterogeneity (I^2^=92.8%); therefore, it is not reported.40,42,43,49,51 Four of these studies displayed a negative association between presence of a mental health diagnosis and receipt of HbA1c, and one found a positive association (OR range: 0.81 to 1.20; median OR=0.89). Four of these estimates were statistically significant (3 negative studies40,42,49 and one positive study43). (Figure 10).

Figure 10 Forest Plot of the Association of Mental Health Diagnosis and Receipt of HbA1c Testing Among Patients With Diabetes

##### LDL-C

Six studies assessed the association of mental health status on the ability to have LDL-C values at goal level.41,45-49 Five of these were conducted with VA users and the sixth46 was a medical chart review of 5 internal medicine practices in Boston. Two studies provided estimates for those with depressive disorders, 4 for those with SMI, one for those with PTSD, and 2 for those diagnosed with any of a broad range of mental illnesses. We were able to perform one meta-analysis for the association of a diagnosis of SMI on the ability to have LDL-C values at goal level. The other results are summarized qualitatively.

Four studies assessed the association of an SMI diagnosis on LDL-C levels, and all met criteria for a random-effects meta-analysis.41,45,46,48 Patients with an SMI diagnosis were no less likely to have LDL-C values at goal level compared to diabetes patient without a diagnosis of mental illness (OR 0.94; 95% CI, 0.70 to 1.26). The summary estimate displayed moderate heterogeneity (I^2^=40.9%) (Figure 11).

Figure 11 Forest Plot of Meta-analysis of the Association of SMI Diagnosis and LDL-C Among Patients With Diabetes

Two studies45,47 assessed the association between a diagnosis of depressive disorders and adequacy of LDL-C control for patients with diabetes; one of these studies47 also provided an estimate for patients with PTSD. Both studies were conducted with VA users and used ICD-9 codes to classify patients with depressive disorders. One study used 2005 national VA EPRP data,45 and the other47 used state-level medical records data. Across both studies, patients with depressive disorders or PTSD were no less likely to have LDL-C values at goal than patients without a diagnosis of mental illness.

Two studies with VA users assessed the association of a diagnosis of composite groups of multiple mental health diagnoses on LDL-C control. One large study of 313,586 VA users with ICD-9 codes for mental health conditions49 reported that patients with mental health diagnoses were more likely to have poor lipid control, defined as no testing done in the past year or an LDL-C value ≥130 mg/dL (OR 1.20; 95% CI, 1.18 to 1.22). The other VA study47 evaluated the impact of a dual diagnosis of PTSD and depression on lipid control and found that patients with a dual diagnosis of PTSD and depression were also more likely to have poor LDL-C control compared to patients without depression or PTSD (OR 1.41; 95% CI, 1.09 to 1.82).

##### Eye Examinations

Nine studies assessed the association of mental health status on the receipt of eye exams among patients with diabetes.38,40,42,43,45,49-52 Three of these studies were conducted with VA users.45,49,51 Four studies provided estimates for those with depressive disorders, 3 for those with SMI, and 5 for those diagnosed with any of a broad range of mental illnesses. We were able to perform meta-analyses for each of these groups of mental health conditions to assess the association of mental health diagnosis on receipt of eye exams among diabetic patients.

Four studies assessed the association of depressive disorders on receipt of eye exams,38,45,50,52 and 3 met criteria for a random-effects meta-analysis.38,45,52 Patients with diagnoses for depressive disorders were no less likely to have eye exams compared to diabetes patients without a diagnosis of mental illness (OR 0.89; 95% CI, 0.56 to 1.41). The summary estimate displayed moderate heterogeneity (I^2^=62.6%) (Figure 12). One other study provided only an HR50; this study also found no significant association of depression and receipt of eye exams (HR 1.02; 99.9% CI, 0.92 to 1.14).

Figure 12 Forest Plot of Meta-analysis of the Association of Depressive Disorders and Eye Exams Among Patients With Diabetes

Three studies assessed the association of SMI on receipt of eye exams, but results could not be pooled.42,45,50 These studies had mixed results. One study conducted with VA users reported a negative association between a diagnosis of SMI and claims for eye exams (OR 0.65; 95% CI, 0.55 to 0.76).45 A non-VA study with Medicare and Medicaid beneficiaries in Massachusetts reported a significant and positive association between receipt of eye exams and a diagnosis of schizophrenia (OR 1.19; 95% CI, 1.06 to 1.33).42 Another non-VA study reported a positive but not significant association of SMI diagnosis and receipt of eye exams (HR 1.36; 99.9% CI, 0.90 to 2.06).50

Five studies assessed the association of a diagnosis of mental illness on receipt of eye exams, and all met criteria for a random-effects meta-analysis, but the summary estimate displayed very high heterogeneity (I^2^=99.4%); therefore, it is not reported.40,42,43,49,51 Again, results were mixed and ranged from negative and statistically significant to positive and not statistically significant (OR range: 0.73 to 1.13; median OR=0.93) (Figure 13). The 2 statistically significant studies both demonstrated negative associations (OR range: 0.73 to 0.93).

Figure 13 Forest Plot of Meta-analysis of the Association of Mental Illness and Eye Exams Among Patients With Diabetes

##### Nephropathy Screening

Five studies assessed the association between mental health status and the receipt of nephropathy screening among patients with diabetes.40,42,43,50,52 None of these studies were conducted with VA users. Two studies provided estimates for those with depressive disorders, 2 for those with SMI, and 3 for those diagnosed with any of a broad range of mental illnesses. We were able to perform one meta-analysis for the association of a diagnosis of broadly defined mental illness on receipt of nephropathy screening among patients with diabetes. The other results will be summarized qualitatively.

Three studies assessed the association of a diagnosis of mental illness on receipt of nephropathy screening among patients with diabetes, and all met criteria for a random-effects meta-analysis, but the summary estimate displayed very high heterogeneity (I^2^=92.4%); therefore, it is not reported.40,42,43 Visual inspection of the forest plot shows little variability in point estimates, which all cluster around no effect of mental illness on receipt of nephropathy screening, but direction of effects were mixed (OR range: 0.96 to 1.10; median OR=1.04) (Figure 14).

Figure 14 Forest Plot of Meta-analysis of the Association of Mental Illness and Nephropathy Screening Among Patients With Diabetes

Two studies assessed the receipt of nephropathy screening among patients with and without depressive disorders.50,52 Both used administrative claims data from private health insurance organizations to assess access to preventive services. Neither study found a significant association between depression and receipt of nephropathy screening among diabetic patients.

Two studies assessed the association of SMI diagnoses on receipt of nephropathy screening.42,50 Results were mixed. One study conducted with claims form a private health insurance organization50 reported a similar rate of screening between those with ICD-9 codes for psychotic disorders and those without a mental health diagnosis (HR 0.94; 99.9% CI, 0.65 to 1.36). The other study, conducted with Medicare and Medicaid beneficiaries in Massachusetts,42 reported a significant and positive association between receipt of nephropathy screening and a diagnosis of schizophrenia/paranoid states (OR 1.39; 95% CI, 1.28 to 1.50) and bipolar disorder (OR 1.34; 95% CI, 1.23 to 1.45) when compared to those without mental illness.

##### Diabetic Foot Exam

Three studies assessed the association of mental health status on the receipt of foot exams among patients with diabetes.38,45,51 Of these, 2 were conducted with VA users,45,51 and the third study was a national population-based study using 2006 BRFSS data.38 Two studies provided estimates for those with depressive disorders, one for those with SMI, and one for those diagnosed with any of a broad range of mental illnesses. We were unable to perform any meta-analyses; results are summarized qualitatively.

Two studies assessed the receipt of foot exams among patients with and without depressive disorders.38,45 One study (n=10,943) used data from the 2005 VA EPRP dataset and registries of VA users with SMI and depression.45 This study found a statistically significant and negative association between a diagnosis of depression and medical records claims of receipt of foot exams in the past year among diabetic VA users (OR 0.85; 95% CI, 0.71 to 0.99). The other study used 2006 BRFSS data (n=16,754)38 and found a similar but statistically insignificant effect of depression as assessed by the Patient Health Questionnaire-8 (PHQ-8) on self-reported foot exams (OR 0.80; 95% CI, 0.62 to 1.04).

One study conducted with VA users reported on the association of SMI diagnoses and receipt of foot exams among patients with diabetes.45 This study used national-level VA claims data and reported a statistically significant and negative association between ICD-9 codes for schizophrenia, bipolar disorder, and other psychosis (OR 0.68; 95% CI, 0.56 to 0.82)45 and receipt of foot exams. One additional national-level study with VA users51 found no difference in foot sensory exams between those with a diagnosis of mental illness without dual diagnosis of SUD and those without mental illness (77.5% vs 78.6%).

##### Blood Pressure Control

Three studies assessed the association between mental health status and adequacy of blood pressure control among patients with diabetes.46,53,54 All 3 used medical records review. Two were conducted with VA users,53,54 and the last study46 used medical records from 5 internal medicine practices in the Boston area. One study provided estimates for those with SMI, and 2 for those diagnosed with any of a broad range of mental illnesses. We were unable to perform any meta-analyses; results are summarized qualitatively.

One study assessed the effect of SMI diagnoses on adequacy of blood pressure control among diabetic patients seen in 5 general internal medicine clinics in Boston.46 This study reported a statistically insignificant effect for patients with ICD-9 codes for schizophrenia (OR 1.22; 95% CI, 0.78 to 1.91).

Two studies, both conducted among VA users, reported on the effect of mental illness on adequacy of blood pressure control and found no statistically significant results. One national-level study with VA users53 found a statistically insignificant effect of ICD-9 codes for schizophrenia, other psychoses, bipolar disorder, or depression on blood pressure control (OR 1.11; 95% CI, 0.99 to 1.25). A final study54 assessed the impact of diagnoses for depression, anxiety, and schizophrenia disorders on adequacy of blood pressure control among patients who had just completed a VA pharmacist-led cardiovascular risk reduction clinic. This study also reported no significant differences in adequacy of blood pressure control for diabetic patients with or without mental illness (HR 0.96; 95% CI, 0.68 to 1.35).

##### Patient with Hyperlipidemia Prescribed a Statin

Only one study assessed the impact of mental illness on receipt of a prescription for a statin among diabetic patient with hyperlipidemia.46 This study was conducted with general internal medicine patients in the Boston area and identified patients with schizophrenia or other psychotic disorders (n=3,808). Investigators reported a statistically significant and negative association between a diagnosis of SMI and prescriptions for statins (OR 0.54; 95% CI, 0.36 to 0.81).

#### Summary of Findings: Diabetes

We identified 14 studies that met inclusion criteria and compared diabetes process of care outcomes (eg, HbA1c testing, LDL-C at goal) among those with and without mental illness.38,40-54 Most studies addressed multiple quality indicators of diabetes. While several studies addressed depressive disorders, SMI, or composite groups of diabetic patients with mental illness, only one study47 assessed the impact of PTSD on diabetes quality of care indicators. We had adequate studies of sufficient homogeneity to conduct 8 meta-analyses for studies addressing disparities with diabetes quality indicators. Yet nearly all meta-analyses displayed high heterogeneity in the estimates, likely due to small number of studies, differences in populations (eg, identification of those with current vs lifetime mental illness), and assessment of outcomes (eg, self-report vs claims data), and study design issues (eg, covariates used in adjusted analysis).

We observed some qualitative differences in care patterns for studies conducted inside the VA versus outside the VA. For composite indicators of diabetes care, the one study conducted outside the VA reported a statistically significant and negative association, while 2 studies conducted with VA users reported mixed results for patients diagnosed with mental illnesses. There was a positive trend of more HbA1c monitoring for VA users with SMI compared to VA users without SMI,45,48 but results were inconsistent in the non-VA studies.42,50 The trend was reversed for diabetic eye exams. The one VA study that assessed receipt of eye exams among diabetic VA users with SMI45 compared to those without mental illness reported that patients with SMI were statistically significantly less likely to received eye exams than VA users without mental illness. In contrast, the 2 studies that assessed receipt of eye exams outside the VA42,50 found that diabetic patients with SMI were more likely to received eye exams than those without mental illness diagnoses, but only one estimate was statistically significant. Three VA studies41,45,48 assessed the adequacy of LDL-C control among patients with SMI and found no significant differences between VA users with and without SMI. Yet, the one study that provided comparative estimates outside the VA46 reported significant and negative effects of SMI on achieving adequate LDL-C control. Patterns for receipt of diabetic foot exams were similar inside and outside the VA; patients with mental illness were less likely to receive foot exams compared to those without mental illness, but estimates were statistically significant only for those patients seeking care inside the VA.

#### Quality of Evidence for Diabetes Care Studies

Total quality scores ranged from 5 to 9 on the NOS, suggesting that all studies were of fair to good quality, with 2 of the studies scoring a 9,^40,49^ one scoring an 8,^52^ 5 scoring a 7,^41-43,51^ 3 scoring a 6,^38,44,45,48^ and 3 scoring a 5^46,47,50^ (Figure 15). The included studies rated high on selection, with all studies receiving a score of 3 or 4 out of 4 possible points. This indicates a high level of representativeness of the selected population and fidelity in ascertainment of the exposure of interest (eg, ICD-9 codes for mental illness). There was significant variability in the area of comparability; more than half the studies (n=10^41-48,50,51^) received zero points, indicating inadequacy of controls for potential confounders (ie, socioeconomic status) in the studies reviewed. Most studies (n=8^40-44,49,51,52^) also displayed high quality in the assessment of outcomes via use of medical records review and adequacy of follow-up windows; they received the maximum of 3 points on this scale. Appendix E provides the scores for each study per domain.

Figure 15 Summary Newcastle-Ottawa Scale Quality Rating for Studies Reporting Diabetes Process of Care Outcomes

Abbreviations: NOS=Newcastle-Ottawa Scale; QA=quality assessment

### Hypertension Care

#### Key Points

- There is limited comparative evidence to describe disparities in hypertension process of care indicators between those with mental illness and those without mental illness. Two studies met inclusion criteria for comparison of hypertension and adequacy of blood pressure control between those with and without mental illness. Both studies were conducted with VA users and were of fair quality.
- A qualitative review found no significant differences in adequacy of blood pressure control between individuals with and without mental illness diagnoses.

#### Description of Included Studies

Two studies met inclusion criteria and comparing adequacy of blood pressure control for individuals with hypertension with and without mental illness.45,55 Table 6 summarizes the characteristics of these studies. We identified one retrospective cohort study and one cross-sectional study. Both studies were conducted exclusively with VA user populations, with data ranging from 2001 to 2005. Both studies used healthcare databases for patients receiving care in outpatient general medicine clinics either at a single facility or as part of a national sample. Of the 24,194 patients across the 2 included studies, most were male in the sixth or seventh decade of life. Of note, one of the 2 studies did not report data on race/ethnicity. Both studies utilized a composite definition (implemented with International Classification of Diseases, 9^th^ Revision, Clinical Modification [ICD-9-CM] diagnosis codes) of mental illness that included schizophrenia and bipolar disorder. Major depressive disorder (n=1), schizoaffective disorder (n=1), and other psychoses (n=2) were also included in the composite definition.

Table 6 Characteristics of Hypertension Studies

Article | Geographic Location; Data Source; Total N | Population: Age in Years; % Female; % White | Mental Health Diagnoses; Measurement | Study Design | Data Source | Outcomes
Dolder, 2005^55^ | San Diego, CA VAMC facility-level clinic database N=178 | Age (mean [SD]): MI=57.1 (9.1) NMI=57.9 (9.0) % Female: MI=5.6 NMI=3.4 % White: MI=58.4 NMI=53.9 | Composite SMI: psychotic disorders (schizophrenia, schizoaffective disorder, or psychosis not otherwise specified) ICD-9 codes | Retrospective cohort | Chart review of VA healthcare system database, calendar year 2001 | BP at goal
Kilbourne, 2008^45^ (Companion: Morden, 2010^53^) | National VA Healthcare system databases N=24,016 for HTN | Age (mean [SD]): Total=67.0 (11.8) % Female: 3.2 % White: NR | Composite SMI: schizophrenia, bipolar disorder, other psychosis Depression: unipolar depression, depressive disorders ICD-9 codes | Cross-sectional | VA National Registries for (1) Psychosis; and (2) Depression; EPRP national quality of care databases, fiscal year 2005 | BP adequately controlled

Abbreviations: BP=blood pressure; CA=California; EPRP=External Peer Review Program; HTN=hypertension; ICD-9=International Classification of Diseases, 9^th^ revision; ICD-9-CM=International Classification of Diseases, 9^th^ Revision, Clinical Modification; MI=mental illness; N=number of participants; NMI=no mental illness; NR=not reported; SD=standard deviation; SMI=serious mental illness, usually schizophrenia, schizoaffective disorder, and bipolar disorder; VA=Veterans Affairs; VAMC=Veteran Affairs Medical Center

#### Synthesis of Findings: Hypertension

We classified studies and organized findings by outcome and by mental health condition. Results are synthesized qualitatively.

##### Proportion of Patients at BP Goal

Two studies assessed the proportion of individuals with hypertension and adequately controlled blood pressure among those with SMI compared to those without SMI.45,55

A small retrospective cohort study assessed the adequacy of blood pressure control among VA patients with hypertension and a psychotic illness (n=89) compared to those without a diagnosed psychiatric disorder (n=89).55 Medical chart review was used to abstract blood pressure measurements in a general medicine clinic, and adequacy of blood pressure control was determined based upon the sixth report of the Joint National Committee on prevention, detection, evaluation, and treatment of high blood pressure.56 The percentage of blood pressure measurements considered adequately controlled (35%) among those with a psychotic disorder was lower than among those without a diagnosed psychiatric disorder (49%). This result was reported as a statistically significant difference with no test statistics reported; we were unable to confirm this finding.

A large cross-sectional study also assessed the adequacy of blood pressure control among VA patients with hypertension and a diagnosis of depression or SMI compared to VA patients without a diagnoses of SMI or depression (n=24,016).45 This medical chart-based study assessed mental health diagnoses by ICD-9 codes and blood pressure outcomes via the 2005 EPRP data. In bivariate and multivariate results, there were no significant differences in adequacy of blood pressure control for the depression group (OR 1.01; 95% CI, 0.93 to 1.09) or the SMI group (OR 1.00; 95% CI, 0.89 to 1.13) compared to patients without a psychiatric diagnosis.

#### Summary of Findings: Hypertension

We reviewed 2 studies that compared blood pressure control in individuals with hypertension with and without mental illness. Both studies were with VA healthcare users. These studies examined a set threshold (BP <140/90) to determine adequacy of blood pressure control. One study found a statistically significant lower proportion of people with adequately controlled blood pressure among individuals with psychotic disorders compared to individuals without any psychiatric disorder, but we were unable to confirm this result.55 The second study found no significant difference in adequacy of blood pressure control between mental illness (ie, SMI, depression) and non-mental illness groups.45

#### Quality of Evidence for Hypertension Studies

Quality ratings were 7 points55 and 6 points, suggesting fair quality studies.45 Both studies received 4 points for selection, suggesting a high degree of quality on the representativeness of the cohorts, ascertainment of exposure, and demonstration that the outcome of interest was not present at the start of the studies. However, neither study displayed a high degree of comparability, and neither controlled for a minimal set of the most important moderating variables. One study55 received 3 points for outcome assessment, while the other45 received 2 points for outcome assessment. Overall, the included studies were high in quality with respect to selection and outcome assessment, but low in quality with respect to comparability due to inadequate control of moderating variables.

### Ischemic Heart Disease Care

#### Key Points

- There is limited comparative evidence to describe disparities in quality of care indicators for ischemic heart disease between those with and without mental illness.
- Only one retrospective cohort study met inclusion criteria. This study received an NOS score of 7, suggesting fair quality. It compared receipt of care for ischemic heart disease between individuals with and without SMI and found no difference in receipt of appropriate pharmacotherapy or rate of invasive intervention procedures post-myocardial infarction.
- No study provided comparative evidence on prescriptions for or adherence to antiplatelet therapy or proportion of individuals at blood pressure goal among those with and without mental illness.

#### Description of Included Studies

One study met inclusion criteria and compared the receipt of process of care outcomes for ischemic heart disease among those with mental illness and those without mental illness57 (Table 7). This study was a retrospective cohort design and was conducted using a state-level population database of administrative claims for Maryland Medicaid enrollees from fiscal years 1994 to 2004. Of the 633 patients with a principle diagnosis of acute myocardial infarction, the majority were female, slightly less than half reported as white race/ethnicity, and 137 were defined as having SMI. The criteria for identifying individuals with SMI were an ICD-9 code for schizophrenia or being disabled (as assessed by Supplemental Security Income) and a diagnosis of bipolar disorder, major depressive disorder, or other mental health diagnosis and specialty mental healthcare use.

Table 7 Characteristics of Ischemic Heart Disease Study

Article | Geographic Location; Data Source; Total N | Population: Age in Years; % Female; % White | Mental Health Diagnoses; Measurement | Study Design | Data Source | Outcomes
McGinty, 2012^57^ | Baltimore or eastern shore, MD State-level, population-based database N=633 | Age (mean [SD]): MI=51.7 (NR) NMI=54.1 (NR) % Female: MI=63.5 NMI=61.5 % White: MI=46.7 NMI=41.9 | Composite of mental health disorders: schizophrenia, bipolar disorder, MDD, other psychoses, organic psychosis, OCD, anxiety disorders ICD-9 codes | Retrospective cohort | Maryland administrative claim files for disabled participants on Medicaid (fiscal years 1994-2004) | 30 days after hospitalization: Cardiac catheterization rate; PTCA (includes catheterization); ACEI/ARB therapy % of patients on statin therapy 1 year after hospitalization: ACEI/ARB therapy: % of patients on statin therapy

Abbreviations: ACEI=angiotensin converting enzyme inhibitor; ARB=angiotensin receptor blocker; ICD-9=International Classification of Diseases, 9^th^ revision; ICD-9-CM=International Classification of Diseases, 9^th^ Revision, Clinical Modification; MDD=major depressive disorder; MI=mental illness; N=number of participants; NMI=no mental illness; NR=not reported; OCD=obsessive-compulsive disorder; PTCA=percutaneous transluminal coronary angioplasty; SD=standard deviation

#### Synthesis of Findings: Ischemic Heart Disease

We classified one study as eligible, organized findings by outcomes of interest, and synthesized the findings qualitatively. Although receipt of appropriate antiplatelet therapy and proportion of individuals at blood pressure goal were outcomes of interest, no identified comparative study reported on these outcomes for patients with ischemic heart disease.

##### Statin Therapy

The included study assessed individuals for a filled statin prescription using pharmacy claims at 1 month and 1 year after index hospitalization for myocardial infarction, stratified by the presence or absence of SMI. While the overall rate of statin use was low at both time points (10.8% to 12.9% and 22.8% to 29.3% at 1 month and 1 year, respectively), no statistically significant differences were observed between patients with SMI and those without SMI.

##### ACEI or ARB Therapy

The study also assessed the percentage of individuals with a filled ACEI or ARB prescription at 1 month and 1 year after index hospitalization for myocardial infarction. The percent of individuals with a claim for an ACEI or ARB was 19.3% at 1 month and 40.0% at 1 year among individuals with SMI (22.3% and 38.5% among non-SMI individuals, respectively). The differences in use of ACEI or ARB between SMI and non-SMI individuals were not statistically significant at either time point.

##### Cardiac Catheterization Rate

The included study also examined rates of invasive therapeutic intervention (eg, cardiac catheterization) during index hospitalization and within 1 month of index hospitalization. There were no significant differences in rates of cardiac catheterization or percutaneous coronary angioplasty during index hospitalization or at 1 month post-hospitalization between SMI and non-SMI individuals.

#### Summary of Findings: Ischemic Heart Disease

We identified only one study the met inclusion criteria and compared receipt of care after index hospitalization for myocardial infarction between individuals with and without mental illness.57 This study found no differences in receipt of appropriate pharmacotherapy or rate of invasive intervention procedures between individuals with and without SMI. Of note, the study reflects a Medicaid population in one eastern state (Maryland) from 1994 to 2004 and may not generalize to other populations.

#### Quality of Evidence for Ischemic Heart Disease

The included study received a total of 7 points (4 for selection, 0 for comparability, and 3 for outcome assessment), suggesting a fair quality study. It did not control for the minimal covariates desired (low quality for comparability), but was rated high quality based on the representativeness of the exposed cohort, sections of non-exposed cohort, and ascertainment of the exposures via ICD-9 codes. The study was also judged to have adequate outcome assessment and adequacy of follow-up of the cohort.

## KEY QUESTION 2 For those with mental illness compared to those without mental illness, do any observed health disparities in preventive care, indicated screening or chronic disease management vary based on race/ethnicity, Veteran status, geographic location, sex, or sexual orientation?

### Key Points

- There are limited data on the interaction effects of mental health status by key moderators. There were no analyses for the subgroups of interest in the eligible studies for cancer screening, immunizations, tobacco screening and referral, or ischemic heart disease.
- One study with 2 separately published analyses assessed mental health disparities in hypertension and diabetes process of care indicators and assessed the differential impact of geographic location (urban vs rural) and race/ethnicity (black vs non-black) on these disparities. No significant differences were noted for either subgroup. Both studies were conducted with VA users.

### Description of Included Studies

We identified one cross-sectional study with 2 separately published analyses45,53 that met inclusion criteria and assessed interaction effects of mental health status and key subgroups (ie, race/ethnicity, Veteran status, geographic location, sex, or sexual orientation). These analyses addressed interaction effects of mental health by race/ethnicity or by geographic setting only. No studies assessed interaction effects of interest between those with and without mental illness for preventive care (ie, tobacco screening and referral, cancer screening, immunizations) or process of care indicators for ischemic heart disease.

### Synthesis of Findings: Key Question 2

We did not have enough studies to perform meta-analyses; therefore, we synthesize the findings qualitatively. The subgroup analyses in the identified studies were limited. The studies reported only interactions by race/ethnicity and by geographic setting. While sex, sexual orientation, and Veteran status were subgroups of interest, no identified comparative study conducted subgroup analyses by these groups.

#### Diabetes Care

One analysis using VA 2005 EPRP data45 examined the association between race/ethnicity (black vs non-black) and differences in HbA1c testing, LDL-C control, sensory foot exams, eye exams, or nephropathy screening in diabetic VA users with mental illness (either SMI or depression) or without mental illness. The study found no significant differences in any of these processes of diabetes care indicators when testing the interaction effect of race/ethnicity by mental health status.

A second analysis using the data from the same study population53 assessed the association between geographic location (rural vs urban) and differences in HbA1c testing, blood pressure control, LDL-C control, sensory foot exams, eye exams, or nephropathy screening in diabetic VA users with SMI or without mental illness. The interaction effect of geographic setting by mental health was not significant for any of the diabetes process of care indicators assessed.

#### Hypertension

One study using data from the VA 2005 EPRP45 examined the association between race/ethnicity (black vs non-black) and differences in blood pressure control in VA users with mental or without mental illness. The study found no significant differences in blood pressure control for black individuals with mental illness versus non-black individuals with mental illness. A second analysis using this same dataset 53 also assessed the association between geographic location (rural vs urban) and differences in blood pressure control for hypertensive VA patients with SMI and hypertensive VA patients without any mental illness. The interaction effect of geographic setting by SMI status on blood pressure control was not significant.

### Summary of Findings: Key Question 2

We identified only one study that assessed the interaction of mental health status and key subgroups of interest (race/ethnicity, geographic setting) for process of care indicators for diabetes and hypertension. No significant differences were noted for either subgroup. There were no analyses for the subgroups of interest in the eligible studies for cancer screening, immunizations, tobacco screening and referral, and ischemic heart disease. No identified studies conducted subgroup analyses by sex, sexual orientation, or Veteran status.

### Quality of Evidence for Key Question 2

The included study received 6 of a possible 9 points for quality as assessed via the NOS, suggesting a fair quality study (Appendix E). It received 4 points for selection, indicating a high level of representativeness of the selected population and fidelity in ascertainment of the exposure of interest (eg, ICD-9 codes for mental illness). However, it received 0 points for comparability, indicating inadequacy of controls for potential confounders. It received 2 points for outcome assessment, indicating moderate quality choices for outcome assessment and adequacy of follow-up times.