# REFERENCES

1 Koranyi EK, Potoczny WM. Physical illnesses underlying psychiatric symptoms. Psychother Psychosom. 1992;58(3-4):155-160. [pmid: 1488499].
2 Wells KB, Rogers W, Burnam A, Greenfield S, Ware JE Jr. How the medical comorbidity of depressed patients differs across health care settings: results from the Medical Outcomes Study. Am J Psychiatry. 1991;148(12):1688-1696. [pmid: 1957931].
3 Yates WR, Mitchell J, Rush AJ, et al. Clinical features of depressed outpatients with and without co-occurring general medical conditions in STAR*D. Gen Hosp Psychiatry. 2004;26(6):421-429. [pmid: 15567207].
4 Nasrallah HA, Meyer JM, Goff DC, et al. Low rates of treatment for hypertension, dyslipidemia and diabetes in schizophrenia: data from the CATIE schizophrenia trial sample at baseline. Schizophr Res. 2006;86(1-3):15-22. [pmid: 16884895].
5 Boyd C, Leff B, Weiss C, Wolff J, Clark R, Richards T. Clarifying Multimorbidity to Improve Targeting and Delivery of Clinical Services for Medicaid Population. Faces of Medicaid Data Series. Center for Health Care Strategies, Inc. 2010. http://www.chcs.org/media/Clarifying_Multimorbidity_for_Medicaid_report-FINAL.pdf. August 20, 2014.
6 Hennekens CH, Hennekens AR, Hollar D, Casey DE. Schizophrenia and increased risks of cardiovascular disease. Am Heart J. 2005;150(6):1115-1121. [pmid: 16338246].
7 Wang PS, Lane M, Olfson M, Pincus HA, Wells KB, Kessler RC. Twelve-month use of mental health services in the United States: results from the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62(6):629-640. [pmid: 15939840].
8 Osborn DP. The poor physical health of people with mental illness. West J Med. 2001;175(5):329-332. [pmid: 11694483].
9 Parks J, Svedsen D, Singer P, Foti M. Morbidity and Mortality in People with Serious Mental Illness. Alexandria, VA. National Association of State Mental Health Program Directors. October. 2006. http://www.nasmhpd.org/docs/publications/MDCdocs/Mortality%20and%20Morbidity%20Final%20Report%208.18.08.pdf. August 20, 2014.
10 Lasser K, Boyd JW, Woolhandler S, Himmelstein DU, McCormick D, Bor DH. Smoking and mental illness: a population-based prevalence study. JAMA. 2000;284(20):2606-2610. [pmid: 11086367].
11 McElroy SL. Obesity in patients with severe mental illness: overview and management. J Clin Psychiatry. Suppl 3. 2009;70:12-21. [pmid: 19570497].
12 Fountoulakis KN, Siamouli M, Panagiotidis P, et al. Obesity and smoking in patients with schizophrenia and normal controls: a case-control study. Psychiatry Res. 2010;176(1):13-16. [pmid: 20079934].
13 de Wit L, Luppino F, van Straten A, Penninx B, Zitman F, Cuijpers P. Depression and obesity: a meta-analysis of community-based studies. Psychiatry Res. 2010;178(2):230-235. [pmid: 20462641].
14 Janney CA, Fagiolini A, Swartz HA, Jakicic JM, Holleman RG, Richardson CR. Are adults with bipolar disorder active? Objectively measured physical activity and sedentary behavior using accelerometry. J Affect Disord. 2014;152-154:498-504. [pmid: 24095103].
15 Janney CA, Ganguli R, Richardson CR, et al. Sedentary behavior and psychiatric symptoms in overweight and obese adults with schizophrenia and schizoaffective disorders (WAIST Study). Schizophr Res. 2013;145(1-3):63-68. [pmid: 23410710].
16 Brown S, Birtwistle J, Roe L, Thompson C. The unhealthy lifestyle of people with schizophrenia. Psychol Med. 1999;29(3):697-701. [pmid: 10405091].
17 Newcomer JW. Metabolic considerations in the use of antipsychotic medications: a review of recent evidence. J Clin Psychiatry. Suppl 1. 2007;68:20-27. [pmid: 17286524].
18 Levinson Miller C, Druss BG, Dombrowski EA, Rosenheck RA. Barriers to primary medical care among patients at a community mental health center. Psychiatr Serv. 2003;54(8):1158-1160. [pmid: 12883146].
19 Kaufman EA, McDonell MG, Cristofalo MA, Ries RK. Exploring barriers to primary care for patients with severe mental illness: frontline patient and provider accounts. Issues Ment Health Nurs. 2012;33(3):172-180. [pmid: 22364429].
20 Mitchell AJ, Malone D, Doebbeling CC. Quality of medical care for people with and without comorbid mental illness and substance misuse: systematic review of comparative studies. Br J Psychiatry. 2009;194(6):491-499. [pmid: 19478286].
21 Lord O, Malone D, Mitchell AJ. Receipt of preventive medical care and medical screening for patients with mental illness: a comparative analysis. Gen Hosp Psychiatry. 2010;32(5):519-543. [pmid: 20851274].
22 Druss BG, Rask K, Katon WJ. Major depression, depression treatment and quality of primary medical care. Gen Hosp Psychiatry. 2008;30(1):20-25. [pmid: 18164936].
23 Druss BG, Rosenheck RA, Desai MM, Perlin JB. Quality of preventive medical care for patients with mental disorders. Med Care. 2002;40(2):129-136. [pmid: 11802085].
24 Kodl MM, Powell AA, Noorbaloochi S, Grill JP, Bangerter AK, Partin MR. Mental health, frequency of healthcare visits, and colorectal cancer screening. Med Care. 2010;48(10):934-939. [pmid: 20706162].
25 Kessner DM, Kalk CE, Singer J. Assessing health quality--the case for tracers. N Engl J Med. 1973;288(4):189-194. [pmid: 4682231].
26 Nolte E, Bain C, McKee M. Diabetes as a tracer condition in international benchmarking of health systems. Diabetes Care. 2006;29(5):1007-1011. [pmid: 16644629].
27 Yu W, Ravelo A, Wagner TH, et al. Prevalence and costs of chronic conditions in the VA health care system. Med Care Res Rev. 2003;60(3 Suppl):146S-167S. [pmid: 15095551].
28 Bresee LC, Majumdar SR, Patten SB, Johnson JA. Prevalence of cardiovascular risk factors and disease in people with schizophrenia: a population-based study. Schizophr Res. 2010;117(1):75-82. [pmid: 20080392].
29 Wells GA, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for Assessing the Quality of Nonrandomised Studies in Meta-analyses. Ottawa Hospital Research Institute (OHRI). 2009. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. August 20, 2014.
30 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
31 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693-2710. [pmid: 12939780].
32 R Core Team. R: A Language and Environment for Statistical Computing. Vienna. R Foundation for Statistical Computing. http://www.R-project.org/. August 20, 2014.
33 Viechtbauer W. Conducting meta-analyses in R with the metafor package. Journal of Statistical Software. 2010;36(3):1-48.
34 Egede LE, Grubaugh AL, Ellis C. The effect of major depression on preventive care and quality of life among adults with diabetes. Gen Hosp Psychiatry. 2010;32(6):563-569. [pmid: 21112446].
35 Lasser KE, Zeytinoglu H, Miller E, Becker AE, Hermann RC, Bor DH. Do women who screen positive for mental disorders in primary care have lower mammography rates?. Gen Hosp Psychiatry. 2003;25(3):214-216. [pmid: 12748035].
36 Pirraglia PA, Sanyal P, Singer DE, Ferris TG. Depressive symptom burden as a barrier to screening for breast and cervical cancers. J Womens Health (Larchmt). 2004;13(6):731-738. [pmid: 15333288].
37 Yee EF, White R, Lee SJ, et al. Mental illness: is there an association with cancer screening among women veterans?. Womens Health Issues. 2011;21(4 Suppl):S195-202. [pmid: 21724141].
38 Egede LE, Ellis C, Grubaugh AL. The effect of depression on self-care behaviors and quality of care in a national sample of adults with diabetes. Gen Hosp Psychiatry. 2009;31(5):422-427. [pmid: 19703635].
39 Duffy SA, Kilbourne AM, Austin KL, et al. Risk of smoking and receipt of cessation services among veterans with mental disorders. Psychiatr Serv. 2012;63(4):325-332. [pmid: 22337005].
40 Druss BG, Zhao L, Cummings JR, Shim RS, Rust GS, Marcus SC. Mental comorbidity and quality of diabetes care under Medicaid: a 50-state analysis. Med Care. 2012;50(5):428-433. [pmid: 22228248].
41 Nelson LA, Graham MR, Lindsey CC, Rasu RS. Adherence to antihyperlipidemic medication and lipid control in diabetic Veterans Affairs patients with psychotic disorders. Psychosomatics. 2011;52(4):310-318. [pmid: 21777713].
42 Leung GY, Zhang J, Lin WC, Clark RE. Behavioral health disorders and adherence to measures of diabetes care quality. Am J Manag Care. 2011;17(2):144-150. [pmid: 21473663].
43 Green JL, Gazmararian JA, Rask KJ, Druss BG. Quality of diabetes care for underserved patients with and without mental illness: site of care matters. Psychiatr Serv. 2010;61(12):1204-1210. [pmid: 21123404].
44 Taveira TH, Pirraglia PA, Cohen LB, Wu WC. Efficacy of a pharmacist-led cardiovascular risk reduction clinic for diabetic patients with and without mental health conditions. Prev Cardiol. 2008;11(4):195-200. [pmid: 19476571].
45 Kilbourne AM, Welsh D, McCarthy JF, Post EP, Blow FC. Quality of care for cardiovascular disease-related conditions in patients with and without mental disorders. J Gen Intern Med. 2008;23(10):1628-1633. [pmid: 18626722].
46 Weiss AP, Henderson DC, Weilburg JB, et al. Treatment of cardiac risk factors among patients with schizophrenia and diabetes. Psychiatr Serv. 2006;57(8):1145-1152. [pmid: 16870966].
47 Trief PM, Ouimette P, Wade M, Shanahan P, Weinstock RS. Post-traumatic stress disorder and diabetes: co-morbidity and outcomes in a male veterans sample. J Behav Med. 2006;29(5):411-418. [pmid: 16865552].
48 Krein SL, Bingham CR, McCarthy JF, Mitchinson A, Payes J, Valenstein M. Diabetes treatment among VA patients with comorbid serious mental illness. Psychiatr Serv. 2006;57(7):1016-1021. [pmid: 16816287].
49 Frayne SM, Halanych JH, Miller DR, et al. Disparities in diabetes care: impact of mental illness. Arch Intern Med. 2005;165(22):2631-2638. [pmid: 16344421].
50 Jones LE, Clarke W, Carney CP. Receipt of diabetes services by insured adults with and without claims for mental disorders. Med Care. 2004;42(12):1167-1175. [pmid: 15550796].
51 Desai MM, Rosenheck RA, Druss BG, Perlin JB. Mental disorders and quality of diabetes care in the veterans health administration. Am J Psychiatry. 2002;159(9):1584-1590. [pmid: 12202281].
52 Lin EH, Katon W, Von Korff M, et al. Relationship of depression and diabetes self-care, medication adherence, and preventive care. Diabetes Care. 2004;27(9):2154-2160. [pmid: 15333477].
53 Morden NE, Berke EM, Welsh DE, McCarthy JF, Mackenzie TA, Kilbourne AM. Quality of care for cardiometabolic disease: associations with mental disorder and rurality. Med Care. 2010;48(1):72-78. [pmid: 19927015].
54 Cohen LB, Taveira TH, Wu WC, Pirraglia PA. Maintenance of risk factor control in diabetic patients with and without mental health conditions after discharge from a cardiovascular risk reduction clinic. Ann Pharmacother. 2010;44(7-8):1164-1170. [pmid: 20501890].
55 Dolder CR, Furtek K, Lacro JP, Jeste DV. Antihypertensive medication adherence and blood pressure control in patients with psychotic disorders compared to persons without psychiatric illness. Psychosomatics. 2005;46(2):135-141. [pmid: 15774952].
56 The sixth report of the Joint National Committee on prevention, detection, evaluation, and treatment of high blood pressure. [Erratum appears in Arch Intern Med 1998 Mar 23;158(6):573]. Arch Intern Med. 1997;157(21):2413-2446. [pmid: 9385294].
57 McGinty EE, Blasco-Colmenares E, Zhang Y, et al. Post-myocardial-infarction quality of care among disabled Medicaid beneficiaries with and without serious mental illness. Gen Hosp Psychiatry. 2012;34(5):493-499. [pmid: 22763001].
58 Manderscheid R, Kathol R. Fostering sustainable, integrated medical and behavioral health services in medical settings. Ann Intern Med. 2014;160(1):61-65. [pmid: 24573665].
59 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.). AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.