# METHODS

## TOPIC DEVELOPMENT

The topic for this review was nominated after a process that included a preliminary review of published peer-reviewed literature, consultation with internal partners and investigators, and consultation with key stakeholders, namely, the Office of Health Equity, Mental Health Services, and Patient Care Services. We further developed and refined the key questions (KQs) based on published, peer-reviewed literature in consultation with VA and non-VA experts.

The final KQs were the following:

KQ 1 Among adult patients, are there health disparities for those with mental illness compared to those without mental illness in the following areas:
  a. Receipt of appropriate preventive care services and indicated screening (eg, cancer screening, immunizations)?
  b. Management of chronic conditions (eg, quality indicators for diabetes care)?
KQ 2 For those with mental illness compared to those without mental illness, do any observed health disparities in preventive care, indicated screening or chronic disease management vary based on race/ethnicity, Veteran status, geographic location, sex, or sexual orientation?

We followed a standard protocol for all steps of this review. Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic Framework

Abbreviations: ACE inhibitor=angiotensin converting enzyme inhibitor; ARB=angiotensin receptor blocker; HbA1c=glycated hemoglobin; KQ=key question; LDL-C=low-density lipoprotein cholesterol; MDD=major depressive disorder; OB/GYN=obstetrics/gynecology; PTSD=posttraumatic stress disorder; VA=Veterans Affairs

## SEARCH STRATEGY

We developed our search strategy in consultation with 2 experienced search librarians. We conducted a primary search of MEDLINE^®^ (via PubMed^®^), The Cochrane Library, Embase^®^, and PsycINFO^®^ from 1994 to February 2014. We restricted the search to articles published from 1994 forward due to the limited use of performance measures prior to the mid-1990s. We used a combination of Medical Subject Heading (MeSH) keywords such as “Mental Disorders,” “Depressive Disorder,” “Diabetes Mellitus,” and “Colorectal Neoplasms” and selected free-text terms (eg, psychotic disorders, eye exams, vaccinations) to search titles and abstracts. We limited the search to articles published in English and involving human subjects 18 years of age and older. The exact search strategies used are provided in Appendix A.

We supplemented the electronic searches with a manual search of the reference lists of systematic and nonsystematic reviews, as well as a set of key primary articles.20,21 All citations were imported into 2 electronic databases (for referencing, EndNote^®^ Version X5, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## STUDY SELECTION

Using prespecified inclusion/exclusion criteria, 2 investigators screened titles and abstracts of articles identified through our search process for potential relevance to the KQs. Articles included by either investigator underwent full-text screening. At the full-text screening stage, 2 independent investigators were required to agree on a final inclusion/exclusion decision. Disagreements were arbitrated by consensus or by a third investigator. The criteria for inclusion or exclusion at both the title/abstract and full-text screening stages for the KQs are detailed in Table 1. In brief, we included U.S.-based comparative studies involving patients with and without bipolar disorder, schizophrenia, schizoaffective disorder, major depressive disorder (or depressive disorders), and post-traumatic stress disorder (PTSD) that reported at least one of the prespecified preventive or chronic disease outcomes.

Table 1 Inclusion/Exclusion Criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | KQ 1a and KQ 1b: Adults with bipolar disorder, schizophrenia, schizoaffective disorder, MDD (or depressive disorders), or PTSD. (For mixed study populations, ≥65% of those with mental health diagnoses were required to have a diagnosis of primary interest. Studies including populations with unspecified mental illness—eg, “chronic mental illness”—were eligible for inclusion only if we were able to isolate the subset of participants without comorbid SUD.) KQ 1b: Insured populations or mixed populations of insured and uninsured, provided one of the following conditions is met: (1) the analysis controls for insurance status; (2) results are reported separately by insurance status; or (3) ≥80% of total population has insurance. | - Children; - Patient samples without a clinical diagnosis (eg, chart diagnosis), administrative code (eg, ICD-9) or research diagnosis for one of the specified mental illnesses; - Uninsured populations (unless meet inclusion criteria exemptions)
Interventions | KQ 1a:; - Age- and risk-level-appropriate breast, colorectal, and cervical cancer screenings; - Age-appropriate immunizations; - Screening and referral for tobacco use; KQ 1b:; - Diabetes care; - Hypertension care; - Ischemic heart disease care | Interventions not listed at left
Comparators | Populations not selected for mental illness or without a diagnosis of mental illness | No non-mental health comparator Population control (eg, general population surveys)
Outcomes | As informed by VA EPRP metrics, the HEDIS process of care indicators, and NQF measures for the following conditions: KQ 1a:; - [underlined: Cancer screening] (as per study definition):; ○ Breast cancer screening (eg, average-risk woman aged 50-75 with one or more mammograms in prior 2 years); ○ Colorectal cancer screening (eg, average-risk adults aged 50+ with annual FOBT, flexible sigmoidoscopy in past 5 years, colonoscopy in past 10 years); ○ Cervical cancer screening (eg, average-risk women aged 21–64 who had cervical cytology performed every 3 years, or women aged 30–64 who had cervical cytology/HPV co-testing performed every 5 years); ○ Composite: 1 or more of the above; - [underlined: Immunizations:] Influenza vaccination in past year; indicated pneumococcal vaccination at any time in past; proportion getting indicated vaccinations; - [underlined: Tobacco use:] Proportion screening for tobacco use; if current smoker, proportion referred for smoking cessation treatments; if current smoker, proportion prescribed tobacco cessation pharmacotherapy; KQ 1b:; - [underlined: Diabetes care:] Composite measure of comprehensive diabetes care or assessment of key process of care indicators: HbA1c testing; LDL-C at goal; proportion with hyperlipidemia prescribed a statin; eye exam; nephropathy screening; diabetic foot exam; blood pressure under control (as defined by what was applicable at the time of the study); - [underlined: Hypertension:] BP adequately controlled (eg, <140/90 during the measurement year); proportion at goal; - [underlined: Ischemic heart disease]: Prescribed or adherence to statin therapy or proportion at BP; prescribed or adherence to ACEI or ARB therapy; prescribed or adherence to antiplatelet therapy (eg, aspirin or clopidogrel); cardiac catheterization rate | Ad hoc performance metrics not endorsed by VA’s EPRP, HEDIS, or NQF
Timing | Studies of any duration | None
Setting | - Studies conducted in the U.S.; - Conducted in non-mental health, outpatient primary care settings (ED, FP, GIM, primary OB/GYN, geriatrics) and selected specialty settings (eg, endocrinology, cardiology) | - Conducted in countries outside the U.S.; - Inpatient setting only; - Mental health specialty care setting only
Study design | - Comparative studies (cohort studies, case-control studies), cross-sectional, pooled patient-level meta-analyses; - sample size ≥100 subjects | - Not a research study (eg, editorial, non-systematic review, letter to the editor); - Exploratory/pilot study; - Studies without a comparator
Publication type | - English language only; - Peer-reviewed articles; - Published from 1994 forward | Non-English articles Abstracts only

Abbreviations: ACEI=angiotensin converting enzyme inhibitor; ARB=angiotensin receptor blocker; BP=blood pressure; ED=emergency department; EPRP=External Peer Review Program; FP=family practice; FOBT=fecal occult blood test; GIM=general internal medicine; HbA1c=glycated hemoglobin; HEDIS=Healthcare Effectiveness Data and Information Set; HPV=human papillomavirus; ICD-9=International Classification of Diseases, 9th revision; KQ=key question; LDL-C=low-density lipoprotein cholesterol; MDD=major depressive disorder; NQF=National Quality Forum; OB/GYN=obstetrics and gynecology; PTSD=posttraumatic stress disorder; SUD=substance use disorder; VA=Veterans Affairs

## DATA ABSTRACTION

Data from published reports were abstracted into a customized DistillerSR database by one investigator and overread by a second investigator. Disagreements were resolved by consensus or by obtaining a third investigator’s opinion when consensus could not be reached. Data elements include descriptors to assess applicability, quality elements, intervention/exposure details, and outcomes. When outcomes were reported in more than one form, the odds ratio (OR), relative risk (RR), or hazard ratio (HR), with 95% confidence intervals (CIs), were preferentially abstracted over percentages or raw data for numerator and denominator.

Key abstraction elements were the following:

- Study characteristics
  ○ Design
  ○ Recruitment dates
  ○ Geographic location and number of sites
  ○ Setting or data source
  ○ Inclusion/exclusion criteria
  ○ Type of comparator
  ○ Mental health conditions of interest represented
  ○ Means of mental health diagnosis determination
  ○ Preventive screening or immunization services examined
  ○ Chronic disease quality measures examined
- Population characteristics (both intervention and comparator groups)
  ○ Veteran status and era of service, if given
  ○ Age, race/ethnicity, sex
  ○ Sexual orientation
- Outcomes
  ○ Mammogram
  ○ Pap smear
  ○ Fecal occult blood test (FOBT) in last year
  ○ Sigmoidoscopy in past 5 years
  ○ Colonoscopy in past 10 years
  ○ Influenza vaccination in last year
  ○ Pneumococcal vaccination ever
  ○ Screening for tobacco use
  ○ Referral for smoking cessation treatment
  ○ Prescribed tobacco-cessation pharmacotherapy
  ○ Glycated hemoglobin (HbA1c) testing
  ○ Low-density lipoprotein cholesterol (LDL-C) at goal
  ○ Eye (or retinal) exam
  ○ Nephropathy screening (urine screen or microalbumin)
  ○ Diabetic foot exam (by provider)
  ○ Blood pressure controlled or proportion of patients at BP goal
  ○ Statin therapy
  ○ Angiotensin converting enzyme inhibitor (ACEI) or angiotensin receptor blocker (ARB) therapy
  ○ Antiplatelet therapy
  ○ Cardiac catheterization rate
  ○ Reported subgroup analyses

Multiple reports from a single study were treated as a single data point. We captured any subgroup analyses of particular interest to our stakeholders, including differential intervention effects by sex, age, and VA healthcare user status. When critical data were missing or unclear in published reports, we requested the data from study authors. Applicability was addressed by examining key features such as the match between the sample and target populations.

## QUALITY ASSESSMENT

Quality assessment was performed by the investigator abstracting or evaluating the included article and overread by a second, highly experienced investigator. Disagreements were resolved by consensus or by arbitration from a third investigator.

We used the Newcastle-Ottawa Scale (NOS) to rate quality of these observational studies.29 The NOS uses a “star system” in which a study is rated on 3 broad perspectives: (1) the selection of the study groups (eg, representativeness of the exposed cohort, ascertainment of the exposure); (2) the comparability of the groups based on analysis or design elements (study controls for the most important factors); and (3) the ascertainment of either the exposure or outcome of interest for case-control or cohort studies, respectively (eg, assessment of outcome by self-report vs record linkages, was follow-up long enough for the outcome to occur). Studies could get a total of 4 points for selection, 2 for comparability, and 3 for assessment of the outcome or exposure for a total of 9 points per study. While not explicitly stated in the NOS rating guidance, we used the following score ranges to qualitatively categorize the overall quality of the included observational studies: 0 to 4=poor quality; 5 to 7=fair quality; 8 to 9=high quality. See Appendix B for a complete version of quality assessment tool.

## DATA SYNTHESIS

We summarized key features of the included studies from the abstracted data. We determined the feasibility of completing a quantitative synthesis (meta-analysis) to estimate summary effects. Feasibility depended on the volume of relevant literature, conceptual homogeneity of the studies, and completeness of the reporting of results. We performed meta-analyses only when there were at least 3 studies with the same outcome based on the rationale that fewer studies do not provide adequate evidence for summary effects. We also took into consideration the conceptual homogeneity of the mental health conditions assessed and pooled studies only if the mental health diagnoses were similar across studies. For example, we pooled studies of SMI cohorts if they were comprised of a single diagnosis (eg, bipolar disorder, schizophrenia only) or multiple SMI diagnoses (composite SMI). We anticipated heterogeneity of effects and hypothesized that VA healthcare user status, sex, race/ethnicity, geographic location, and sexual orientation might be associated with variation in the estimates. We planned subgroup analyses to explore these moderators as potential sources of heterogeneity; however, we did not have sufficient studies to conduct these analyses.

If quantitative synthesis was feasible, we calculated summary odds ratios (ORs). Because of the relatively small number of studies, we used a random-effects model with the Knapp and Hartung method to adjust the standard errors of the estimated coefficients.30,31 We evaluated statistical heterogeneity by visual inspection and Cochran’s Q and I^2^ statistics. If heterogeneity was high (I^2^≥75%), we present forest plots without a pooled estimate of effect and report the range and median of point estimates from individual studies instead. We used the metafor package of the R statistical software.32,33

When quantitative synthesis was not possible, we summarized findings qualitatively. We gave more weight to the evidence from higher quality studies with more precise estimates of effect. A qualitative synthesis focused on documenting and identifying patterns in the interventions across conditions and outcome categories. We analyzed potential reasons for inconsistency in effects across studies by evaluating differences in the study population, intervention, comparator, and outcome definitions.

## RATING THE BODY OF EVIDENCE

We graded the overall strength of evidence (SOE) based on the specific criteria outlined by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) approach. We provide our assessment of the overall SOE across all included study designs by assessing 4 domains: risk of bias, consistency, directness, and precision. For risk of bias, we considered basic (eg, cohort or cross-sectional) and detailed study design (eg, how the outcome was assessed). When possible, we used results from meta-analyses when evaluating consistency (forest plots, tests for heterogeneity), precision (confidence intervals), and strength of association. These domains were considered qualitatively, and a summary rating of high, moderate, low, or very low SOE was assigned. This 4-level rating scale consists of the following definitions:

- High—We are very confident that the true effect lies close to that of the estimate of the effect. (Alternative: Further research is very unlikely to change our confidence on the estimate of effect.)
- Moderate—We are moderately confident in the effect estimate; the true effect is likely to be close to the estimate of effect, but there is a possibility that it is substantially different. (Alternative: Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.)
- Low—Our confidence in the effect estimate is limited: the true effect may be substantially different from the estimate of the effect. (Alterative: Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.)
- Very low—We have very little confidence in the effect estimate; the true effect is likely to be substantially different from the estimate of effect. (Alternative: Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect.)

## PEER REVIEW

A draft of this report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is provided in Appendix C.