# INTRODUCTION

The burden of mental illness among Veterans is substantial, but the burden of medical comorbidities among people with mental illness is also noteworthy. Medical illnesses such as diabetes and cardiovascular disease affect a disproportionate number of people with mental illness.1-3 More than 90% of individuals with serious mental illness (SMI) have co-occurring chronic medical conditions such as hypertension, cardiovascular disease, hyperlipidemia, or diabetes.4,5 These chronic medical conditions when co-occurring with mental illness are more detrimental to overall health than in the general population.6 For example, people with comorbid mental illness and chronic medical conditions have higher hospitalization rates and healthcare costs than people with comparable chronic medical conditions alone.7 Furthermore, preventable medical conditions are the leading cause of premature death among people with SMI.8,9

Effects of mental illness on the individual’s capacity to maintain health, adverse effects of medications used to treat mental illness, and lower quality of medical care have been implicated as contributors to disparities in health and healthcare between people with and without mental illness. Individual-level modifiable risk factors, such as smoking,10 obesity,11-13 and physical inactivity14-16 are highly prevalent in people with mental illness. Moreover, adverse effects of medications used to treat mental illness (notably second-generation antipsychotics) also increase the risk of conditions such as hyperglycemia, hyperlipidemia, and obesity.17 People dually diagnosed with mental illness and chronic medical conditions may also face greater challenges to receiving recommended preventive care and screenings. People with mental illness report lower perceived quality of primary care (eg, comprehensiveness of care, coordination of care) compared to those in the general population.18,19 Some studies examining healthcare quality report differences in rates of recommended services between those with and without mental illness.20,21 For example, people with mental illness are less likely to receive recommended breast, cervical, and colorectal cancer screening,22-24 and less likely to receive recommended immunizations.23

Healthcare systems are complex organizations, and assessing quality within these organizations is challenging. One approach to evaluating quality of care within healthcare systems is the use of tracer conditions as quality indicators.25 This approach focuses on targeted prevalent conditions for which strong evidence and agreement concerning appropriate processes of care (eg, annual foot exams for patients with diabetes) and goals of therapy (eg, blood pressure [BP]<140/90) exist, making it possible to uncover deficits in complex healthcare systems.26 Chronic medical illnesses such as diabetes, heart disease, and hypertension are highly prevalent among Veterans Affairs (VA) patients: an estimated 72% have one or more chronic medical illnesses (compared to 40% to 50% of other U.S. adults), and over half have at least 2 such conditions.27 Thus, diabetes, hypertension, and ischemic heart disease may serve as ideal tracer conditions to assess quality in the VA healthcare system as a whole. In similar fashion, receipt of selected recommended preventive screenings and services provides an opportunity to examine system-level quality of care among certain subpopulations.

Disparities in health between people with and without mental illness are common.20,28 In order to guide future research and policy decisions for the VA, the VA Office of Heath Equity partnered with the Evidence-based Synthesis Program (ESP) to conduct a systematic review of health disparities in quality indicators of healthcare among adults with mental illness. This report evaluates comparative studies that assess a broad range of preventive care and chronic disease management quality indicators. The findings will be used to identify areas in need of further research and potential areas for policy change within the VA healthcare system.