# SUMMARY OF FINDINGS TABLES

Appendix Table F-1 Preventive Services: Summary of Findings for Differences in Receipt of Services for Those With Versus Those Without a Mental Health Disorder

Outcome; (Number of Studies); Conclusion | Mental Health Diagnoses | Main Findings | Differences in Study Findings: VA vs Non-VA studies
Cancer Screening : Process Outcomes
Breast cancer screening: Mammography (n=6) Limited evidence for small to large disparities | -Depressive disorders: 4 studies | -Depressive disorders (3 of 4 studies): significant negative differences (OR range: 0.48 to 0.82) | Both VA and non-VA studies displayed negative associations between mental health diagnoses and receipt of mammography; however, not all comparisons were statistically significant.
Breast cancer screening: Mammography (n=6) Limited evidence for small to large disparities | -PTSD: 1 study | -PTSD (1 study): statistically significantly lower rate (37% vs 56%) | Both VA and non-VA studies displayed negative associations between mental health diagnoses and receipt of mammography; however, not all comparisons were statistically significant.
Breast cancer screening: Mammography (n=6) Limited evidence for small to large disparities | -Psychotic disorders: 1 study | -Psychotic disorders (1 study): no significant difference in rates | Both VA and non-VA studies displayed negative associations between mental health diagnoses and receipt of mammography; however, not all comparisons were statistically significant.
Breast cancer screening: Mammography (n=6) Limited evidence for small to large disparities | -Composites of mental health conditions: 2 studies | -Composite groups (2 of 2 studies): negative trends; only 1 was statistically significant (OR range: 0.78 to 0.79) | Both VA and non-VA studies displayed negative associations between mental health diagnoses and receipt of mammography; however, not all comparisons were statistically significant.
Cervical cancer screening: Pap smear (n=5) Limited evidence for small to moderate disparities | -Depressive disorders: 3 studies | -Depressive disorders (meta-analysis of 3 studies): significantly lower odds (OR 0.87; 95% CI, 0.77 to 0.98) | Both VA and non-VA displayed negative associations between mental health diagnoses and receipt of Pap smears; however, not all comparisons were statistically significant.
Cervical cancer screening: Pap smear (n=5) Limited evidence for small to moderate disparities | -Composite groups of mental health conditions: 2 studies | -Composite groups (1 of 2 studies): a statistically significant negative effect (OR 0.87; 95% CI, 0.78 to 0.96) | Both VA and non-VA displayed negative associations between mental health diagnoses and receipt of Pap smears; however, not all comparisons were statistically significant.
Colorectal cancer screening: FOBT, flexible sigmoidoscopy, colonoscopy (n=5) Limited evidence for small to large disparities | -Depressive disorders: 3 studies | -Depressive disorders (2 of 3 studies): significant negative associations (OR range: 0.43 to 0.90; median OR=0.85) | Both VA and non-VA studies showed a significant and negative association of depression on receipt of colorectal cancer screenings. For persons diagnosed with depressive disorders, the impact of these disparities were greater in the VA (OR=0.43 in VA study vs OR=0.90 in non-VA study)
Colorectal cancer screening: FOBT, flexible sigmoidoscopy, colonoscopy (n=5) Limited evidence for small to large disparities | -PTSD (1 study) | -PTSD (1 VA study): no significant difference
Colorectal cancer screening: FOBT, flexible sigmoidoscopy, colonoscopy (n=5) Limited evidence for small to large disparities | -Psychotic disorders (1 study) | -Psychotic disorders (1 VA study): a negative and significant association (p-value<0.001)
Colorectal cancer screening: FOBT, flexible sigmoidoscopy, colonoscopy (n=5) Limited evidence for small to large disparities | -Composite groups of mental health conditions (3 studies) | -Composite groups (2 of 3 VA studies): negative, significant associations (OR range: 0.85 to 0.95 and p<0.01)
Immunizations: Process Outcomes
Influenza vaccinations (n=3) Limited evidence for small to moderate disparities | -Depressive disorders: 2 studies | -Depressive disorders (1 of 2 studies): a positive, significant association not to receive vaccination (OR=1.24) | One VA study reported significant negative association. The 2 non-VA studies reported mixed results.
Influenza vaccinations (n=3) Limited evidence for small to moderate disparities | -Composite group of mental health conditions (excluding substance use): 1 study | -Composite groups (1 VA study): a significant negative association (OR 0.90; 95% CI, 0.87 to 0.94) | One VA study reported significant negative association. The 2 non-VA studies reported mixed results.
Pneumococcal vaccinations (n=2) Limited, inconsistent evidence for small disparities | -Depressive disorders: 1 study | -Depressive disorders (1 VA study): a negative, significant association (OR=0.95) | One VA study reported a negative, significant association. One non-VA study found no association.
Pneumococcal vaccinations (n=2) Limited, inconsistent evidence for small disparities | -Composite group of mental health conditions (excluding substance use): 1 study | -Composite groups (1 study): no significant association | One VA study reported a negative, significant association. One non-VA study found no association.
Screening and Referral for Tobacco Use: Process Outcomes
Screening for tobacco use (n=1) Limited evidence for no health disparities | Composite group of mental health conditions: 1 study | Composite group (1 VA study): a significant, positive association (OR=1.17) | Not applicable, both to screening and referral for tobacco use: only 1 VA study
Referral for tobacco use (n=2) Limited, inconsistent evidence of disparities | -Composite group of mental health conditions: 1 study | -Composite groups (1 VA study): a significant positive association (OR=1.1) | Not applicable, both to screening and referral for tobacco use: both were VA studies
Referral for tobacco use (n=2) Limited, inconsistent evidence of disparities | -Depressive disorders, schizophrenia, bipolar disorder and PTSD: 1 VA study | -Separate estimates for different mental health diagnoses (1 study): mixed results | Not applicable, both to screening and referral for tobacco use: both were VA studies
Prescriptions for tobacco cessation pharmacotherapy (n=1) Limited, inconsistent evidence for disparities | -Depressive disorders, PTSD, schizophrenia and bipolar disorder: 1 VA study | -Separate estimates (1 study): depressive disorders, a significant positive association (OR=1.07); PTSD, a significant positive association (OR=1.14); schizophrenia and bipolar disorder, no association | Not applicable, both to screening and referral for tobacco use: only 1 VA study

Abbreviations: CI=confidence interval; FOBT=fecal occult blood test; n=number of studies; OR=odds ratio; PTSD=posttraumatic stress disorder; VA=Veterans Affairs

Appendix Table F-2 Chronic Disease Management Services: Summary of Findings for Differences in Receipt of Services for Those With Versus Those Without a Mental Health Disorder

Outcome; (Number of Studies); Conclusion | Mental Health Diagnoses | Main Findings | Differences in Study Findings: VA vs Non-VA studies
Diabetes Care: Process Outcomes
Composite measure of care (n=3) Limited, inconsistent evidence for small disparities | Composite group of mental health conditions: 3 studies | Composite group (2 of 3 studies): a significant, negative association (OR range: 0.72 to 0.83) | One non-VA study: a negative, significant association 2 VA studies: mixed results
HbA1c testing (n=10) Limited, inconsistent evidence for small disparities | -Depressive disorders: 4 studies | -Depressive disorders (1 of 4 studies): a statistically significant, negative association (OR=0.53) | Depression: VA and non-VA studies reported inconsistent results
HbA1c testing (n=10) Limited, inconsistent evidence for small disparities | -SMI: 4 studies | -SMI (3 of 4 studies): positive trends (OR range: 1.02 to 1.51); 2 of these were statistically significant | SMI: VA studies showed positive trends for more HbA1c monitoring; one non-VA study’s results were inconsistent
HbA1c testing (n=10) Limited, inconsistent evidence for small disparities | -Composite groups of mental health conditions: 5 studies | -Composite groups (5 of 5 studies): 4 negative associations; 1 positive association (OR range: 0.81 to 1.20; median OR=0.89). Four estimates were statistically significant (3 negative, 1 positive). | Composite groups: Most VA and non-VA studies displayed a small, negative impact of mental illness on HbA1c testing. One non-VA study reported a statistically significant, positive effect.
Eye examinations (n=9) Limited, inconsistent evidence for small to moderate disparities | -Depressive disorders: 4 studies | -Depressive disorders (meta-analysis of 3 studies): No difference (OR 0.89; 95% CI, 0.56 to 1.41; I^2^=62.2%). | Depressive disorders: No differences
Eye examinations (n=9) Limited, inconsistent evidence for small to moderate disparities | -SMI: 3 studies | -SMI (3 studies): Results were mixed; 1 statistically significant negative effect (OR 0.65; 95% CI, 0.55 to 0.76); 2 positive effects, but only 1 statistically significant (OR 1.19; 95% CI, 1.06 to 1.33) | SMI: One VA study reported a statistically significant, negative effect; two non-VA studies showed positive associations, although only one was statistically significant
Eye examinations (n=9) Limited, inconsistent evidence for small to moderate disparities | -Composite groups of mental health disorders: 5 studies | -Composite groups (5 studies): Results were mixed, ranging from negative and statistically significant (n=2) to positive and not significant (OR range: 0.73 to 1.13; median OR=0.93). | Composite groups: In both non-VA and VA studies, there were statistically significant negative results; other results not significant. Of note, disparities were less in the VA versus the non-VA study (OR=0.93 vs 0.73).
Nephropathy screening (n=5) Limited evidence for health disparities | -Depressive disorders: 2 studies | -Depressive disorders (2 of 2 studies):no significant associations | Not applicable; all were non-VA studies
Nephropathy screening (n=5) Limited evidence for health disparities | -SMI: 2 studies | -SMI (2 studies): results were mixed; one study found no significant differences (HR 0.94; 99.9% CI, 0.65 to 1.36); other study found significant, positive associations for schizophrenia/paranoia (OR 1.39; 95% CI, 1.28 to 1.50) and bipolar disorder (OR 1.34; 95% CI, 1.23 to 1.45) | Not applicable; all were non-VA studies
Nephropathy screening (n=5) Limited evidence for health disparities | -Composites of mental health conditions: 3 studies | -Composite group: effects were mixed (OR range: 0.96 to 1.10; median OR=1.04), indicating no clear effect or association | Not applicable; all were non-VA studies
Foot exam (n=3) Limited, inconsistent evidence for small to moderate disparities | -Depressive disorders: 2 studies | -Depressive disorders (1 of 2 studies): a statistically significant, negative effect (OR 0.85; 95% CI, 0.71 to 0.99) | Across all conditions, VA and non-VA studies showed negative associations, but the effect was significant only for the VA studies.
Foot exam (n=3) Limited, inconsistent evidence for small to moderate disparities | -SMI: 1 study | -SMI (1 study): a negative, statistically significant effect (OR 0.68; 95% CI, 0.56 to 0.82) | Across all conditions, VA and non-VA studies showed negative associations, but the effect was significant only for the VA studies.
Foot exam (n=3) Limited, inconsistent evidence for small to moderate disparities | -Composite group: 1 study | -Composite group (1 study): no difference | Across all conditions, VA and non-VA studies showed negative associations, but the effect was significant only for the VA studies.
Statin prescription for hyperlipidemia (n=1) Very limited evidence; no support for disparities | -Schizophrenia: 1 study | -Schizophrenia (1 study): no differences | Not applicable; only 1 non-VA study
Diabetes Care: Intermediate Outcomes
LDL-C at goal level (n=6) Limited, inconsistent evidence for disparities | -Depressive disorders: 2 studies | -Depressive disorders (2 of 2 studies): no significant association | For depression, not applicable
LDL-C at goal level (n=6) Limited, inconsistent evidence for disparities | -SMI: 4 studies | -SMI (meta-analysis of 4 studies): no difference (OR 0.94; 95% CI, 0.70 to 1.26) | For SMI, the non-VA study reported a significant, negative association, while 3 VA studies were not statistically significant.
LDL-C at goal level (n=6) Limited, inconsistent evidence for disparities | -PTSD: 1 study | -PTSD (1 study): no differences | For PTSD, not applicable
LDL-C at goal level (n=6) Limited, inconsistent evidence for disparities | -Composite groups: 2 studies | -Composite groups (2 of 2 studies): statistically significantly negative effects for poor control (OR range: 1.20 to 1.41) | For composite groups, the 2 VA studies reported significant, negative associations.
Blood pressure control (n=3) Limited evidence; no support for disparities | -SMI: 1 study | -SMI (1 study): No statistically significant differences | Not applicable; SMI was a non-VA study, and both composite groups were VA studies
Blood pressure control (n=3) Limited evidence; no support for disparities | -Composite groups: 2 studies | -Composite groups (2 of 2 studies): No statistically significant differences | Not applicable; SMI was a non-VA study, and both composite groups were VA studies
Hypertension Care: Intermediate Outcomes
Blood pressure control (n=2) Limited evidence; no support for disparities | -Composite groups of mental health conditions: 2 studies | -Composite groups (1 of 2 studies): less likelihood of adequate control (35% vs 49%) for individuals with psychotic disorders; reported as statistically significant (test statistic not provided) | Not applicable; both were VA studies.
Ischemic Heart Disease Care: Process Outcomes
Statin therapy (n=1) Limited evidence; no support for disparities | -Composite group of mental health conditions: 1 study | -Composite group (1 study): no significant association (1 month: 10.8% to 12.9%; 1 year: 22.8% to 29.3%) | Not applicable; only 1 non-VA study
ACEI or ARB therapy Limited evidence; no support for disparities | -Composite group of mental health conditions: 1 study | -Composite group (1 study): no significant association (1 month: 19.3% to 22.3%; 1 year: 40.0% to 38.5%) | Not applicable; only 1 non-VA study
Cardiac catheterization rate (n=1) Limited evidence; no support for disparities | -Composite group of mental health conditions: 1 study | -Composite group (1 study): no significant differences in rates during index hospitalization or at 1 month post hospitalization | Not applicable; only 1 non-VA study

Abbreviations: ACEI=angiotensin converting enzyme inhibitor; ARB=angiotensin receptor blocker; CI=confidence interval; HbA1c=glycated hemoglobin; HR=hazard ratio; LDL-C=low density lipoprotein cholesterol; n=number of studies; OR=odds ratio; PTSD=posttraumatic stress disorder; SMI=serious mental illness, usually schizophrenia, schizoaffective disorder, and bipolar disorder; VA=Veterans Affairs