# NEWCASTLE-OTTAWA SCALE COHORT RATINGS

Study | Selection | Comparability | Outcome | Targeted Preventive Service or Chronic Disease
Desai, 2002^1^ | ✓✓✓✓ | – | ✓✓✓ | Chronic disease: DM
Dolder, 2005^2^ | ✓✓✓✓ | – | ✓✓✓ | Chronic disease: HTN
Druss, 2002^3^ | ✓✓✓ | – | ✓✓ | Preventive services: CA screening^*^ Immunization Smoking cessation
Druss, 2008^4^ | ✓✓✓ | ✓✓ | – | Preventive services: CA screening Immunization
Druss, 2012^5^ | ✓✓✓✓ | ✓✓ | ✓✓✓ | Chronic disease: DM
Duffy, 2012^6^ | ✓✓✓ | ✓✓ | – | Preventive service: Smoking cessation
Egede, 2010^7^ (Companion: Egede, 2009^8^) | ✓✓✓ | ✓✓ | ✓✓ | Preventive services: CA screening Immunization Chronic disease: DM
Frayne, 2005^9^ | ✓✓✓✓ | ✓✓ | ✓✓✓ | Chronic disease: DM
Green, 2010^10^ | ✓✓✓✓ | – | ✓✓✓ | Chronic disease: DM
Jones, 2004^11^ | ✓✓✓ | – | ✓✓ | Chronic disease: DM
Kilbourne, 2008^12^ (Companion: Morden, 2010^13^) | ✓✓✓✓ | – | ✓✓ | Chronic diseases: DM, HTN
Kodl, 2010^14^ | ✓✓✓✓ | – | ✓✓✓ | Preventive service: CA screening (colorectal only)
Krein, 2006^15^ | ✓✓✓✓ | – | ✓✓ | Chronic disease: DM
Lasser, 2003^16^ | ✓✓✓ | – | ✓✓ | Preventive service: CA screening (breast only)
Leung, 2011^17^ | ✓✓✓✓ | – | ✓✓✓ | Chronic disease: DM
Lin, 2004^18^ | ✓✓✓ | ✓✓ | ✓✓✓ | Chronic disease: DM
McGinty, 2012^19^ | ✓✓✓ | – | ✓✓✓ | Chronic disease: IHD
Nelson, 2011^20^ | ✓✓✓✓ | – | ✓✓✓ | Chronic disease: DM
Pirraglia, 2004^21^ | ✓✓✓ | ✓✓ | ✓ | Preventive service: CA screening (breast and cervical only)
Taveira, 2008^22^ (Companion: Cohen, 2010^23^) | ✓✓✓ | – | ✓✓✓ | Chronic disease: DM
Trief, 2006^24^ | ✓✓✓ | – | ✓✓ | Chronic disease: DM
Weiss, 2006^25^ | ✓✓✓ | – | ✓✓ | Chronic disease: DM
Yee, 2011^26^ | ✓✓✓✓ | – | ✓✓✓ | Preventive service: CA screening

* CA screening implies breast, cervical, and colorectal unless otherwise indicated.

Abbreviations: CA=cancer; DM=diabetes mellitus; HTN=hypertension; IHD=ischemic heart disease

## References to Appendix E

1 Desai MM, Rosenheck RA, Druss BG, Perlin JB. Mental disorders and quality of diabetes care in the veterans health administration. Am J Psychiatry. 2002;159(9):1584-1590. [pmid: 12202281].
2 Dolder CR, Furtek K, Lacro JP, Jeste DV. Antihypertensive medication adherence and blood pressure control in patients with psychotic disorders compared to persons without psychiatric illness. Psychosomatics. 2005;46(2):135-141. [pmid: 15774952].
3 Druss BG, Rosenheck RA, Desai MM, Perlin JB. Quality of preventive medical care for patients with mental disorders. Med Care. 2002;40(2):129-136. [pmid: 11802085].
4 Druss BG, Rask K, Katon WJ. Major depression, depression treatment and quality of primary medical care. Gen Hosp Psychiatry. 2008;30(1):20-25. [pmid: 18164936].
5 Druss BG, Zhao L, Cummings JR, Shim RS, Rust GS, Marcus SC. Mental comorbidity and quality of diabetes care under Medicaid: a 50-state analysis. Med Care. 2012;50(5):428-433. [pmid: 22228248].
6 Duffy SA, Kilbourne AM, Austin KL, et al. Risk of smoking and receipt of cessation services among veterans with mental disorders. Psychiatr Serv. 2012;63(4):325-332. [pmid: 22337005].
7 Egede LE, Grubaugh AL, Ellis C. The effect of major depression on preventive care and quality of life among adults with diabetes. Gen Hosp Psychiatry. 2010;32(6):563-569. [pmid: 21112446].
8 Egede LE, Ellis C, Grubaugh AL. The effect of depression on self-care behaviors and quality of care in a national sample of adults with diabetes. Gen Hosp Psychiatry. 2009;31(5):422-427. [pmid: 19703635].
9 Frayne SM, Halanych JH, Miller DR, et al. Disparities in diabetes care: impact of mental illness. Arch Intern Med. 2005;165(22):2631-2638. [pmid: 16344421].
10 Green JL, Gazmararian JA, Rask KJ, Druss BG. Quality of diabetes care for underserved patients with and without mental illness: site of care matters. Psychiatr Serv. 2010;61(12):1204-1210. [pmid: 21123404].
11 Jones LE, Clarke W, Carney CP. Receipt of diabetes services by insured adults with and without claims for mental disorders. Med Care. 2004;42(12):1167-1175. [pmid: 15550796].
12 Kilbourne AM, Welsh D, McCarthy JF, Post EP, Blow FC. Quality of care for cardiovascular disease-related conditions in patients with and without mental disorders. J Gen Intern Med. 2008;23(10):1628-1633. [pmid: 18626722].
13 Morden NE, Berke EM, Welsh DE, McCarthy JF, Mackenzie TA, Kilbourne AM. Quality of care for cardiometabolic disease: associations with mental disorder and rurality. Med Care. 2010;48(1):72-78. [pmid: 19927015].
14 Kodl MM, Powell AA, Noorbaloochi S, Grill JP, Bangerter AK, Partin MR. Mental health, frequency of healthcare visits, and colorectal cancer screening. Med Care. 2010;48(10):934-939. [pmid: 20706162].
15 Krein SL, Bingham CR, McCarthy JF, Mitchinson A, Payes J, Valenstein M. Diabetes treatment among VA patients with comorbid serious mental illness. Psychiatr Serv. 2006;57(7):1016-1021. [pmid: 16816287].
16 Lasser KE, Zeytinoglu H, Miller E, Becker AE, Hermann RC, Bor DH. Do women who screen positive for mental disorders in primary care have lower mammography rates?. Gen Hosp Psychiatry. 2003;25(3):214-216. [pmid: 12748035].
17 Leung GY, Zhang J, Lin WC, Clark RE. Behavioral health disorders and adherence to measures of diabetes care quality. Am J Manag Care. 2011;17(2):144-150. [pmid: 21473663].
18 Lin EH, Katon W, Von Korff M, et al. Relationship of depression and diabetes self-care, medication adherence, and preventive care. Diabetes Care. 2004;27(9):2154-2160. [pmid: 15333477].
19 McGinty EE, Blasco-Colmenares E, Zhang Y, et al. Post-myocardial-infarction quality of care among disabled Medicaid beneficiaries with and without serious mental illness. Gen Hosp Psychiatry. 2012;34(5):493-499. [pmid: 22763001].
20 Nelson LA, Graham MR, Lindsey CC, Rasu RS. Adherence to antihyperlipidemic medication and lipid control in diabetic Veterans Affairs patients with psychotic disorders. Psychosomatics. 2011;52(4):310-318. [pmid: 21777713].
21 Pirraglia PA, Sanyal P, Singer DE, Ferris TG. Depressive symptom burden as a barrier to screening for breast and cervical cancers. J Womens Health (Larchmt). 2004;13(6):731-738. [pmid: 15333288].
22 Taveira TH, Pirraglia PA, Cohen LB, Wu WC. Efficacy of a pharmacist-led cardiovascular risk reduction clinic for diabetic patients with and without mental health conditions. Prev Cardiol. 2008;11(4):195-200. [pmid: 19476571].
23 Cohen LB, Taveira TH, Wu WC, Pirraglia PA. Maintenance of risk factor control in diabetic patients with and without mental health conditions after discharge from a cardiovascular risk reduction clinic. Ann Pharmacother. 2010;44(7-8):1164-1170. [pmid: 20501890].
24 Trief PM, Ouimette P, Wade M, Shanahan P, Weinstock RS. Post-traumatic stress disorder and diabetes: co-morbidity and outcomes in a male veterans sample. J Behav Med. 2006;29(5):411-418. [pmid: 16865552].
25 Weiss AP, Henderson DC, Weilburg JB, et al. Treatment of cardiac risk factors among patients with schizophrenia and diabetes. Psychiatr Serv. 2006;57(8):1145-1152. [pmid: 16870966].
26 Yee EF, White R, Lee SJ, et al. Mental illness: is there an association with cancer screening among women veterans?. Womens Health Issues. 2011;21(4 Suppl):S195-202. [pmid: 21724141].