# CHARACTERISTICS OF INCLUDED STUDIES

Article; Study Design | Targeted Preventive Service or Chronic Disease | Geographic Location; Data Source; Total N | Population: Age in Years; % Female; % White | Mental Health Diagnoses; Measurement | Data Sources | Outcomes
Desai, 2002^1^ Retrospective cohort | Chronic disease: DM | National VA Healthcare System databases N=36,528 | Age (mean [SD]): MI=62.2 (12.0) NMI=65.9 (10.6) % Female: MI=18.9 NMI=11.1 % White: MI=67.9 NMI=61.2 | Composite of mental health conditions: psychiatric disorders (excluding SUD and dual diagnosis) ICD-9 codes | VA computerized medical records: 1999 VA EPRP; Patient encounter files; Patient treatment files (January 1998 to December 1999) | HbA1c testing; Diabetic foot exam; Eye exam
Dolder, 2005^2^ Retrospective cohort | Chronic disease: HTN | San Diego, CA VAMC facility-level clinic database N=178 | Age (mean [SD]): MI=57.1 (9.1) NMI=57.9 (9.0) % Female: MI=5.6 NMI=3.4 % White: MI=58.4 NMI=53.9 | Composite SMI: psychotic disorders (schizophrenia, schizoaffective disorder, or psychosis not otherwise specified) ICD-9 codes | Chart review of VA healthcare system database, calendar year 2001 | BP at goal
Druss, 2002^3^ Cross-sectional | Preventive services: Cancer screening^*^ Immunization Smoking cessation | National VA Healthcare systems (general and specialty) N=113,495 | Age (mean [SD]): MI=60.8 (12.9) NMI=66 (11.5) % Female: MI=20.1 NMI=13.1 % White: MI=67.6 NMI=62.1 | Composite of mental health conditions: psychiatric disorders (excluding substance abuse) ICD-9 codes | EPRP chart review, 1998-1999; Patient Encounter, OP, and Patient Treatment files | Cancer screening: Breast cancer screening; Cervical cancer screening; Colorectal cancer screening: FOBT, sigmoidoscopy, or colonoscopy Immunization: Influenza vaccine past year; Pneumococcal vaccine ever Smoking cessation: Proportion screened for tobacco use; Proportion referred for smoking cessation treatments
Druss, 2008^4^ Cross-sectional | Preventive services: Cancer screening Immunization | National National-level survey data N=30,081 | Age (mean [SD]): MI=42.2 (0.41) NMI=46.9 (0.18) % Female: MI=70 NMI=55 % White: MI=76 NMI=76 | Major depression Score ≥3 on CIDI-SF | NHIS, 1999 | Cancer screening: Breast cancer screening; Cervical cancer screening; Colorectal cancer screening: FOBT Immunization: Influenza vaccination in past year
Druss, 2012^5^ Retrospective cohort | Chronic disease: DM | National National-level database N=657,628 | Age (mean [SD]): MI=48.2 (0.4) NMI:=47.7 (0.6) % Female: MI=63.7 NMI=68.2 % White: MI=56.8 NMI=51.7 | Composite of mental health conditions: any mental health diagnosis excluding dementia/ delirium ICD-9 codes | Medicaid eligibility, service utilization, and payment database (2003-2004) | HbA1c testing; Eye exam; Nephropathy screening; At least 2 HEDIS quality indicators completed in a year
Duffy, 2012^6^ Cross-sectional | Preventive service: Smoking cessation | National National-level VHA outpatient survey N=224,193 | Age (category): <45: 3.4% 45-64: 37.4% ≥65: 59.2% % Female: 3.5% White: 83.1 | Schizophrenia Bipolar disorder Depressive disorder PTSD ICD-9 codes | VHA Outpatient SHEP (fiscal year 2007) | Proportion prescribed tobacco cessation pharmacotherapies
Egede, 2010^7^ (Companion: Egede, 2009^8^) Cross-sectional | Preventive services: Cancer screening Immunization Chronic disease: DM | National Randomized survey N=16,754 | Age (category): MI: 18-34: 8.1% 35-49: 28.3% 50-64: 42.5% 65+: 21.1% NMI: 18-34: 4.6% 35-49: 17.4% 50-64: 38.4% 65+: 39.6% % Female: MI=61.6 NMI=46.3 % White: MI=63 NMI: 62 | Major depression among those with diabetes PHQ-8 | BRFSS 2006 | Cancer screening: Breast cancer screening; Cervical cancer screening; Colorectal cancer screening: FOBT, sigmoidoscopy, or colonoscopy Immunization: Flu shot in past year; Pneumonia vaccine ever DM: HbA1c testing; Diabetic foot exam; Eye exam
Frayne, 2005^9^ Cross-sectional | Chronic disease: DM | National VA databases and survey N=313,586 | Age (category; n): MI: <55: 28,339 55-64: 16,051 65-74: 20,429 ≥75: 11,981 NMI: <55: 39,780 55-64: 47,357 65-74: 94,241 ≥75: 55,645 % Female: MI=3.3 NMI=1.8 % White: MI=73.4 NMI=74.5 | Composite of mental health conditions: depressed mood, anxiety, psychosis, manic symptoms, SUD, personality disorders, dissociative symptoms, somatoform symptoms, impulse control disorders, eating disorders ICD-9 codes | 6 sources (October 1997-September 1999): DEpiC; Medicare claims; VA National Patient Care Database; VHA Health Care Analysis Information Group (lab data); VHA Pharmacy Database; 1999 Large Health Survey of Veteran Enrollees | No HbA1c testing;^†^ No eye exam;^†^ LDL-C not at goal;^†^ Composite diabetes outcome: no monitoring for diabetes (no HbA1c test done, no LDL-C-test done, and no eye exam done)^†^
Green, 2010^10^ Retrospective cohort | Chronic disease: DM | Atlanta, GA Facility-level database N=8,817 | Age (mean [SD]): MI=49.4 (10.2) NMI=55.6 (11.8) % Female: MI=61.4 NMI=64.3 % White: MI=11.7 NMI=4.3 | Schizophrenia Mood disorders ICD-9 codes | ER, urgent care, and PC records (OP), 2004-2005, from urban, public hospital | HbA1c testing; Eye exam; Nephropathy screening
Jones, 2004^11^ Retrospective cohort | Chronic disease: DM | Iowa State-level population-based database N=26,020 | Age (mean [SD]): MI=47.1 (9.4) NMI=48.4 (10.2) % Female: MI=50.2 NMI=46.0 % White: NR | Mood disorders Psychotic disorders ICD-9 codes | Administrative claims data from BCBS of Iowa (January 1996 to December 2001) | HbA1c testing; Eye exam; Nephropathy screening
Kilbourne, 2008^12^ (Companion: Morden, 2010^13^) Cross-sectional | Chronic diseases: DM HTN | National VA Healthcare system databases N=24,016 for HTN N=10,943 for DM | Age (mean [SD]): Total=67.0 (11.8) % Female: 3.2 % White: NR | Composite SMI: schizophrenia, bipolar disorder, other psychosis Depression: unipolar depression, depressive disorders ICD-9 codes | VA National Registries for (1) Psychosis; and (2) Depression; EPRP national quality of care databases, fiscal year 2005 | DM: BP under control; LDL-C at goal; Diabetic foot exam; Eye exam; HbA1c testing not received^†^ HTN: BP adequately controlled
Kodl, 2010^14^ Retrospective cohort | Preventive service: Cancer screening (colorectal only) | Minneapolis, MN Facility-level VA Healthcare system N=855 | Age (mean [SD]): MI=59.4 (6.6) NMI=63.8 (7.6) % Female: MI=20.3 NMI=35.6 % White: MI=48 NMI=68.7 | PTSD Composite of mental health conditions: unipolar or bipolar depression, bipolar disorder, MDD, depressive disorders SMI composite: schizophrenia, delusional disorders, nonorganic psychoses ICD-9 codes | Electronic medical record (1996-2006) | Colorectal cancer screening: FOBT, sigmoidoscopy, or colonoscopy
Krein, 2006^15^ Cross-sectional | Chronic disease: DM | National VA Healthcare System registries N=36,546 | Age (mean [SD]): Total=58 (12) % Female: MI=4.0 NMI=: 14.0 % White: MI=64.0 NMI=69.0 | Composite SMI: schizophrenia, schizoaffective disorder, bipolar disorder, other nonorganic psychoses, paranoid states, affective psychoses ICD-9-CM codes | VA National Psychosis Registry & Healthcare Analysis and Information Group/QUERI-DM (diabetes registry), October 1997 to September 1998 | HbA1c testing; LDL-C at goal
Lasser, 2003^16^ Retrospective cohort | Preventive service: Cancer screening (breast only) | Cambridge & Somerville, MA Local-level database from PC centers N=526 | Age range: 40 to 70 % Female=100 % White=52.1 | -PTSD -Composite of mental health Psychotic disorders Mood disorders (depressive disorders) PRIME-MD (modified) | PRIME-MD records, 1998 to “present” (precise year/date not specified), from CHA administrative files | Breast cancer screening;
Leung, 2011^17^ Cross-sectional | Chronic disease: DM | Massachusetts State-level database N=10,6174 | Average age range: 52 to 65 yr % Female: MI=64.0 NMI=68.2 % White: MI=79.2 NMI=82.4 | Schizophrenia Bipolar disorder Depression/ anxiety Other MI ICD-9 codes | Massachusetts Medicaid & Medicare, 2004-2005 | HbA1c testing; Eye exam; Nephropathy screening
Lin, 2004^18^ Prospective cohort | Chronic disease: DM | Seattle, WA HMO member survey N=4,385 | Age (mean [SD]): Total=63.3 (13.4) % Female=48.7 % White=NR | Major depression Depressive disorders PHQ-9 | GHC diabetes registry, 2001-2003 | No HbA1c testing;^†^ No eye exam;^†^ No nephropathy screening within past year among patients not taking ACEI^†^
McGinty, 2012^19^ Retrospective cohort | Chronic disease: IHD | Baltimore or eastern shore, MD State-level, population-based database N=633 | Age (mean [SD]): MI=51.7 (NR) NMI=54.1 (NR) % Female: MI=63.5 NMI=61.5 % White: MI=46.7 NMI=41.9 | Composite of mental health disorders: schizophrenia, bipolar disorder, MDD, other psychoses, organic psychosis, OCD, anxiety disorders ICD-9 codes | Maryland administrative claim files for disabled participants on Medicaid (fiscal years 1994-2004) | 30 days after hospitalization: Cardiac catheterization rate; PTCA (includes catheterization); ACEI/ARB therapy % of patients on statin therapy 1 year after hospitalization: ACEI/ARB therapy: % of patients on statin therapy
Nelson, 2011^20^ Cross-sectional | Chronic disease: DM | Kansas City, KS Facility-level VAMC database N=124 | Age (mean [SD]): MI=57.9 (7.0) NMI=57.9 (2.2) % Female=0 % White: MI=35.5 NMI=69.5 | Composite SMI: schizophrenia, schizoaffective disorder, and psychosis NOS) ICD-9 codes | Computerized patient record system (CPRS) for 2008 | LDL-C at goal
Pirraglia, 2004^21^ Prospective cohort | Preventive service: Cancer screening (breast and cervical only) | Boston, MA; Chicago, IL; Detroit, MI; Los Angeles & Oakland, CA; Hudson County, NJ; Pittsburgh, PA Databases N=3,297 | Age (category): >50 years: (10.2%) % Female=100 % White=47 | Major depression (high ≥21) Depressive disorder (moderate 16-20) CES-D | SWAN longitudinal Cohort, 1996-1997 | Breast cancer screening; Cervical cancer screening
Taveira, 2008^22^ (Companion: Cohen, 2010^23^) Cross-sectional | Chronic disease: DM | Providence, RI VAMC facility-level database N=297 | Age (mean [SD]): MI=59.9 (9.4) NMI=68.5 (9.3) % Female: MI=4.1 NMI=1.1 % White: MI=49.6 NMI=39.8 | Schizophrenia Mood disorders (including depression and bipolar disorder) Depressive disorder Anxiety Dissociative and somatoform disorders PTSD ICD-9 codes | VAMC electronic medical records from CRRC January 2001-January 2002^‡^ | Composite diabetes outcome: achieve at goal levels for at least 2 of these 3 values: SBP, LDL-C, or HbA1c
Trief, 2006^24^ Retrospective cohort | Chronic disease: DM | New York (state) VA Healthcare Network Upstate New York facility-level database N=14,438 | Average age range:^§^ MI: 59.6 to 64.3 NMI: 69.5 % Female: 0 % White: NR | PTSD with depression PTSD without depression Depression without PTSD ICD-9 codes | Veterans Health Information Systems and Technology Architecture (VistA) for PC visits (July 1, 2003 to October 4, 2004) | LDL-C at goal
Weiss, 2006^25^ Cross-sectional | Chronic disease: DM | Boston, MA 5 internal medicine practices N=3,808 | Age (mean [SD]): MI=62 (15) NMI=65 (13) % Female: MI=57.9 NMI=48.6 % White: MI=72.0 NMI=71.2 | Schizophrenia and other psychotic disorders ICD-9 codes | Review of charts or electronic medical records (January 1, 2000 to July 31, 2003) | Proportion with hyperlipidemia prescribed a statin; LDL-C at goal; BP under control
Yee, 2011^26^ Retrospective cohort | Preventive service: Cancer screening | New Mexico State-level VA Healthcare system N=606 | Age (mean [SD]): MI=57.2 (5.1) NMI=57.7 (5.7) % Female=100 % White: MI=42 NMI=20 | Composite of mental health conditions: anxiety, depressed mood, dissociative symptoms, eating disorders, impulse control or somatoform disorders, manic symptoms, personality disorders, psychosis, and SUD ICD-9 codes | NMVAHCS database (includes any clinic type), October 1, 2003 to September 30, 2006 | Breast cancer screening; Cervical cancer screening; Colorectal cancer screening: FOBT, sigmoidoscopy, or colonoscopy

* Cancer screening implies breast, cervical, and colorectal unless otherwise indicated.

† Inversions for BP under control, HbA1c tested, eye exam received, nephropathy screen performed, and LDL-C at goal will be derived mathematically.

‡ Range of years for data source differed in companion study, Cohen 2010,^23^ where they were listed as 2001 to 2003.

§ Age range given for MI because this represents several different categories (PTSD with and without depression, depression alone); age range NOT given for NMI because only one category.

Abbreviations: ACEI=angiotensin converting enzyme inhibitor; ARB=angiotensin receptor blocker; BCBS=Blue Cross Blue Shield; BP=blood pressure; BRFSS=Behavioral Risk Factor Surveillance Survey; CES-D=Center for Epidemiologic Studies Depression Scale; CHA=Cambridge Health Alliance; CIDI-SF=Composite International Diagnostic Interview-Short Form; CPRS=Computerized Patient Record System; CRRC=Community Resource and Referral Center; DEpiC=Diabetes Epidemiology Cohort; DM=diabetes mellitus; EPRP=External Peer Review Program; ER=emergency room; FOBT=fecal occult blood test; GHC=Group Health Cooperative; HbA1c=glycated hemoglobin; HEDIS=Healthcare Effectiveness Data and Information Set; HMO=health maintenance organization; HTN=hypertension; ICD-9=International Classification of Diseases, 9^th^ revision; ICD-9-CM=International Classification of Diseases, 9^th^ Revision, Clinical Modification; IHD=ischemic heart disease; LDL-C=low density lipoprotein cholesterol; MDD=major depressive disorder; MI=mental illness; N=number of participants; NHIS=National Health Interview Survey; NMI=no mental illness; NMVAHCS=New Mexico VA Health Care System; NR=not reported; OCD=obsessive-compulsive disorder; OP=outpatient; PC=primary care; PHQ-8=Patient Health Questionnaire-8; PHQ-9=Patient Health Questionnaire-9; PRIME-MD=Primary Care Evaluation of Mental Disorders; PTCA=percutaneous transluminal coronary angioplasty; PTSD=posttraumatic stress disorder; QUERI-DM=Diabetes Mellitus Quality Enhancement Research Initiative; SBP=systolic blood pressure; SD=standard deviation; SHEP=Survey of Healthcare Experiences of Patients; SMI=serious mental illness, usually schizophrenia, schizoaffective disorder, and bipolar disorder; SUD=substance use disorder; SWAN=Study of Women’s Health Across the Nation; VA=Veterans Affairs; VAMC=Veteran Affairs Medical Center; VHA=Veterans Health Administration; VistA=Veterans Health Information Systems and Technology Architecture (electronic health record system)

## References to Appendix D

1 Desai MM, Rosenheck RA, Druss BG, Perlin JB. Mental disorders and quality of diabetes care in the veterans health administration. Am J Psychiatry. 2002;159(9):1584-1590. [pmid: 12202281].
2 Dolder CR, Furtek K, Lacro JP, Jeste DV. Antihypertensive medication adherence and blood pressure control in patients with psychotic disorders compared to persons without psychiatric illness. Psychosomatics. 2005;46(2):135-141. [pmid: 15774952].
3 Druss BG, Rosenheck RA, Desai MM, Perlin JB. Quality of preventive medical care for patients with mental disorders. Med Care. 2002;40(2):129-136. [pmid: 11802085].
4 Druss BG, Rask K, Katon WJ. Major depression, depression treatment and quality of primary medical care. Gen Hosp Psychiatry. 2008;30(1):20-25. [pmid: 18164936].
5 Druss BG, Zhao L, Cummings JR, Shim RS, Rust GS, Marcus SC. Mental comorbidity and quality of diabetes care under Medicaid: a 50-state analysis. Med Care. 2012;50(5):428-433. [pmid: 22228248].
6 Duffy SA, Kilbourne AM, Austin KL, et al. Risk of smoking and receipt of cessation services among veterans with mental disorders. Psychiatr Serv. 2012;63(4):325-332. [pmid: 22337005].
7 Egede LE, Grubaugh AL, Ellis C. The effect of major depression on preventive care and quality of life among adults with diabetes. Gen Hosp Psychiatry. 2010;32(6):563-569. [pmid: 21112446].
8 Egede LE, Ellis C, Grubaugh AL. The effect of depression on self-care behaviors and quality of care in a national sample of adults with diabetes. Gen Hosp Psychiatry. 2009;31(5):422-427. [pmid: 19703635].
9 Frayne SM, Halanych JH, Miller DR, et al. Disparities in diabetes care: impact of mental illness. Arch Intern Med. 2005;165(22):2631-2638. [pmid: 16344421].
10 Green JL, Gazmararian JA, Rask KJ, Druss BG. Quality of diabetes care for underserved patients with and without mental illness: site of care matters. Psychiatr Serv. 2010;61(12):1204-1210. [pmid: 21123404].
11 Jones LE, Clarke W, Carney CP. Receipt of diabetes services by insured adults with and without claims for mental disorders. Med Care. 2004;42(12):1167-1175. [pmid: 15550796].
12 Kilbourne AM, Welsh D, McCarthy JF, Post EP, Blow FC. Quality of care for cardiovascular disease-related conditions in patients with and without mental disorders. J Gen Intern Med. 2008;23(10):1628-1633. [pmid: 18626722].
13 Morden NE, Berke EM, Welsh DE, McCarthy JF, Mackenzie TA, Kilbourne AM. Quality of care for cardiometabolic disease: associations with mental disorder and rurality. Med Care. 2010;48(1):72-78. [pmid: 19927015].
14 Kodl MM, Powell AA, Noorbaloochi S, Grill JP, Bangerter AK, Partin MR. Mental health, frequency of healthcare visits, and colorectal cancer screening. Med Care. 2010;48(10):934-939. [pmid: 20706162].
15 Krein SL, Bingham CR, McCarthy JF, Mitchinson A, Payes J, Valenstein M. Diabetes treatment among VA patients with comorbid serious mental illness. Psychiatr Serv. 2006;57(7):1016-1021. [pmid: 16816287].
16 Lasser KE, Zeytinoglu H, Miller E, Becker AE, Hermann RC, Bor DH. Do women who screen positive for mental disorders in primary care have lower mammography rates?. Gen Hosp Psychiatry. 2003;25(3):214-216. [pmid: 12748035].
17 Leung GY, Zhang J, Lin WC, Clark RE. Behavioral health disorders and adherence to measures of diabetes care quality. Am J Manag Care. 2011;17(2):144-150. [pmid: 21473663].
18 Lin EH, Katon W, Von Korff M, et al. Relationship of depression and diabetes self-care, medication adherence, and preventive care. Diabetes Care. 2004;27(9):2154-2160. [pmid: 15333477].
19 McGinty EE, Blasco-Colmenares E, Zhang Y, et al. Post-myocardial-infarction quality of care among disabled Medicaid beneficiaries with and without serious mental illness. Gen Hosp Psychiatry. 2012;34(5):493-499. [pmid: 22763001].
20 Nelson LA, Graham MR, Lindsey CC, Rasu RS. Adherence to antihyperlipidemic medication and lipid control in diabetic Veterans Affairs patients with psychotic disorders. Psychosomatics. 2011;52(4):310-318. [pmid: 21777713].
21 Pirraglia PA, Sanyal P, Singer DE, Ferris TG. Depressive symptom burden as a barrier to screening for breast and cervical cancers. J Womens Health (Larchmt). 2004;13(6):731-738. [pmid: 15333288].
22 Taveira TH, Pirraglia PA, Cohen LB, Wu WC. Efficacy of a pharmacist-led cardiovascular risk reduction clinic for diabetic patients with and without mental health conditions. Prev Cardiol. 2008;11(4):195-200. [pmid: 19476571].
23 Cohen LB, Taveira TH, Wu WC, Pirraglia PA. Maintenance of risk factor control in diabetic patients with and without mental health conditions after discharge from a cardiovascular risk reduction clinic. Ann Pharmacother. 2010;44(7-8):1164-1170. [pmid: 20501890].
24 Trief PM, Ouimette P, Wade M, Shanahan P, Weinstock RS. Post-traumatic stress disorder and diabetes: co-morbidity and outcomes in a male veterans sample. J Behav Med. 2006;29(5):411-418. [pmid: 16865552].
25 Weiss AP, Henderson DC, Weilburg JB, et al. Treatment of cardiac risk factors among patients with schizophrenia and diabetes. Psychiatr Serv. 2006;57(8):1145-1152. [pmid: 16870966].
26 Yee EF, White R, Lee SJ, et al. Mental illness: is there an association with cancer screening among women veterans?. Womens Health Issues. 2011;21(4 Suppl):S195-202. [pmid: 21724141].