# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | Yes. No comments. | Thank you.
2 | Yes. No comments. | Thank you.
3 | Yes. No comments. | Thank you.
4 | Yes. No comments. | Thank you.
5 | Yes. No comments. | Thank you.
6 | Yes. No comments. | Thank you.
7 | Yes. No comments | Thank you.
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | No. No comments. | Thank you.
2 | No. No comments. | Thank you.
3 | No. No comments. | Thank you.
4 | No. No comments. | Thank you.
5 | No. No comments. | Thank you.
6 | No. No comments. | Thank you.
7 | No. No comments. | Thank you.
Question 3: Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No. No comments. | Thank you.
2 | No. No comments. | Thank you.
3 | No. No comments. | Thank you.
4 | No. No comments. | Thank you.
5 | No. No comments. | Thank you.
6 | No. No comments. | Thank you.
7 | No. No comments. | Thank you.
Question 4: Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report
1 | Overall this is a good report, highlighting the need for more studies in this area. I do have two suggestions for improving the report:; 1. In several places in the report (I will use the Summary section as an example) the section introduction indicates that there are health disparities for people with mental illness (page 73, lines 10-12). Yet, this is not consistent with the report findings (page 74, lines 11-14 and page 74, lines 21-22). Both of these statements note mixed results.; 2. On page 40, line 29, the authors note that “Smokers with psychiatric disorders were “slightly” but significantly more likely to be referred to tobacco cessation programs….. The term slightly should be deleted given that it is not used consistently in the report when the OR is a difference of 0.1 above or below 1.0 | Thank you.; 1. We have addressed the inconsistences in language in the final report.; 2. We have deleted “slightly” from this sentence.
2 | This is an excellent report, clear and without bias. The design is excellent, focusing on evidence-based performance measures for chronic disease management and preventive care for individuals with mental illness. The only suggestions I have involve minor editorial issues. These would be probably discovered at some point, but I’m including them just in case. I noticed a number of these in the Executive Summary, and stopped noting them - the errors seem to be replicated in the main text of the report. P. 3 line 16 should mental diagnosis be diagnoses? Line 33 is there a word missing - should it be: focus ON key differences? Line 42 should read “After applyING eligibility criteria...” | Thank you. We have addressed these editorial issues in the final report.
2 | P 4 line 41 should be “...patients with psychiatric...” Line 51 extra “in” at end of line Line 55 is ‘outcomes’ supposed to be after ‘pharmacotherapies’? I think it would work without that word. | We have addressed these editorial issues in the final report.
2 | P 5 line 36 ‘patient’ should be patients Line 58 fragment: ‘All studies with VA health care users.’ Huh? | We have addressed these editorial issues in the final report.
2 | P 6 line 42 patient should be patients P 7 line 36 finding should be findings P 13 Table 1 líne 14 include should be included p. 16 line 53 - should be diagnoses instead of diagnosis ...and so on. | We have addressed these editorial issues in the final report.
3 | In this clearly written, comprehensive, and methodologically sound evidence-based synthesis, authors examine data related to disparities in quality of care for common medical illnesses among those with mental health disorders. Individuals suffering from mental illness frequently carry concurrent chronic medical diagnoses. In such individuals, the clinical and economic effects of these comorbid medical conditions tend to be more pronounced. In light of the relatively high prevalence of both chronic medical conditions and mental health illnesses in the VA population, quantifying disparities in quality of care and understanding the mechanism of such disparities is a topic of great importance to the health of the Veteran population. | Thank you.
3 | The authors performed a systematic review of studies examining performance on process and outcome measures of quality for common preventive services and chronic medical conditions among individuals with and without mental illness. They also identified studies examining predictors of these disparities. Across 25 identified studies, they found relatively weak support for disparities in quality of care, though studies conducted in VA were more likely to show a negative effect of mental illness on quality indicators. Few studies were available to examine predictors of variation in quality of care. Overall, the literature was deemed to be of low methodological quality. | Thank you.
3 | The work is timely, with clearly stated objectives, a well-defined scope, and appropriate methods. The review is comprehensive, and the data are clearly presented. I detect no evidence of bias. It is notable that VA studies were qualitatively more likely to report disparities than non-VA studies. One wonders if this might be due to differences in the severity of mental illness in VA versus non-VA population. Additionally, as the authors allude to in their discussion of policy implications (p. 75, line 56), the quality measures that were examined differ considerably in whether they assess simple processes of care (e.g., check hemoglobin A1C) versus relatively complex outcomes (completion of a screening colonoscopy). I have only minor comments for your consideration. | Thank you.
3 | Methods: 1) Page 2, line 31 (and p. 12, line 35): The search strategy only included articles published between 1994-2014. Why were older articles not included? I suspect this has to do with the limited use of performance measures prior to the mid-1990s, but it would be valuable to clarify the reason here. 2) Why was the work limited to articles published in English? | 1) We have clarified our rationale for restricting the search to articles published from 1994 onward (which does have to do with the limited use of performance measures before the mid-1990s). It is noteworthy that we did not identify any eligible studies published prior to 2002. 2) We limited the scope to U.S.-based studies to increase the applicability of the findings.
3 | Results: 3) The authors do not present results according to performance measure type (process, intermediate outcome, outcome, etc). If data in individual studies are available for such an analysis, it could shed light on the relative role of patient- versus provider-level factors in contributing to disparities. For instance, are disparities less apparent for process measures (such as prescription of anti-hypertensives, which is largely under the control of the provider) than for linked outcome measures (blood pressure control, which depends on the patient filling the prescription and regularly taking the medication)? The authors do allude to this on pp. 76 (line 56) when discussing how the complexity of care can affect performance on quality measures. The data on diabetes management also present these data, though it is not framed in terms of the type of quality measure. | 3) We had too few studies to conduct such an analysis. We have, however, organized the (newly added) Summary of Findings tables (Appendix F in the final report) by type of outcome.
4 | The review itself was fine. My comments are addressed to the summary of clinical and policy implications which I found to be rather generic. Perhaps this starts with the analytic framework (p12) which mentions some modifying factors but in only a very superficial way. In short, there is little attention to context at any of the multiple levels in the process. For example, the reviewed studies were conducted in an environment of changing performance measures, whether HEDIS or VA. It would help to have a timeline to put the studies into their own context. In discussing the evidence gaps, it is not clear how additional studies of the type already undertaken will help other than making us more certain about the modesty of the effects. I guess that the main policy implication at this point is that there shouldn’t be effort given to this topic. Perhaps this is what they author means when she states on p78 “VA and other healthcare systems should consider their clinical and policy needs when deciding whether to invest in research to address gaps in evidence.” I think that there are other research gaps that relate more to outcomes as well as how care is actually given. This might require very different kinds of studies. | Thank you for these comments. We agree that these studies were conducted in a changing environment. We limited our search to include those studies most relevant to the current context and did not identify any eligible studies before 2002. As all studies were clustered in the same timeframe, we did not have adequate studies to assess time trends.
5 | It is impressive, and unfortunate, how few papers (N=26) on the subject met criteria for inclusion in this meta-analysis/review article. That is the first major finding of the paper - that much work remains simply to determine if there are health disparities in the populations of interest. | Thank you.
5 | With the possible, limited, exception of diabetes, the body of literature on health disparities in mentally ill persons (screening, obtaining medical care, access to medical care, etc) is inadequate to make many definitive statements. This is an important contribution of this review article. | Thank you.
5 | In the entire set of papers reviewed, only 14 were conducted with Veterans. Again, this speaks volumes about how this area of inquiry has been understudied in VA. | Slightly more than half of the studies reviewed in the final report (12/23) were conducted by VA researchers using VA data. We think this is a strength of our review and enhances the applicability of our findings to the VA context.
5 | 75% of the selected studies utilized data on broad ranges of mental disorders collapsed into presence/absence data (i.e., mental illness present or absent). Unfortunately, this is not adequate granularity for many of the clinical questions of import. This is not the fault of the ESP review, but rather a problem of researchers looking at mental illnesses as monolithic. Imagine if we did the same for “medical illnesses” and collapsed terminal cancers with mild hypertension and acne rosacea. What sense could we make out of such collapsed data? The same applies for these studies, most of which excluded SMI (a group of diagnoses that have in common severity and persistence of one or more mental illnesses) or collapsed those conditions with depression and other disorders which share little in common with the SMI group of conditions. | We agree that this is a considerable limitation of the literature we identified and have now highlighted this in the Limitations section.
5 | This paper demonstrates that even though there were 16 studies on diabetes and mental illnesses, many gaps remain and the results of the analyses may be clinically uninterpretable. For example, VA screens for HbA1c and LDL in those at risk, which includes patients treated with second generation antipsychotics, but what about the medical treatment for, and compliance with, treatment for those schizophrenic patients who screen positive? The literature is not illuminating in this regard, leaving open significant clinical research questions that should be pursued. | Thank you for this observation. While beyond the scope of this review, these are important clinical questions.
5 | This paper does a fine job of pointing out the substantial weaknesses of the English literature to date on most of the questions posed for the review. An additional limitation that I don’t believe I saw listed is that the least “connected” patients with one or more mental illnesses are not enrolled in primary care at VA facilities at all, and a majority of those are believed not to be seen by anyone outside VA for their basic medical care and screenings. The data reported in most of the 26 papers do not take this important issue into account, which may explain some of the conflicting or counterintuitive results. | This is an excellent point, but we are unable to explore it in the current review. We only included studies that recruited patients from non-mental health primary care settings and selected specialty medical care settings. We also limited the review to studies of insured populations. If a study included mixed populations of insured and uninsured individuals, it could still be included if the analysis controlled for insurance status, results were reported separately by insurance status, or ≥80% of the total population had insurance. These eligibility requirements may have excluded some studies; however, we sought to include studies that were of greatest applicability to the VA Health Care System.
5 | The authors are to be commended for their work on this difficult project and for shedding light on this important and understudied topic. Some believe that the basic step of identifying health disparities in patients with one or more mental illnesses is adequate to move on to “solving” the disparities problem for the 1/3 of patients in VA care who have at least one psychiatric diagnosis. The paragraph on gaps in the research on page 14 dispels this myth. This is coupled with the overall rating of the strength of the evidence (in either direction) as “low.” I particularly appreciated the importance of the following statement in the review: “Though several of the included studies were conducted in VA user populations, there are notable gaps in research which the use of VA data may be well positioned to address.” | Thank you.
5 | Typos: Line 36, page 5; line 17, page 8 | We have addressed these editorial issues in the final report.
5 | I am pleased to see that the limitation on the data in all papers for sexual orientation and gender identity is specifically mentioned in this review. Our own work in OHE has demonstrated substantial disparities in both medical and psychiatric disorders (listed separately and not collapsed) for transgender Veterans. This is another potential confounder in the studies selected for review. This was part of “key question 2” and the authors appropriately note that various demographic parameters of import to the study of disparities in health care went unaddressed in the literature reviewed. | Thank you.
5 | This article provides the basis to chart a course for the study of disparities in medical care in Veterans with one or more mental illnesses. It is an excellent synthesis of the overall weak existing literature on this important topic, and it should be the basis for developing projects that have not been done to fill the research gap in this heterogeneous, vulnerable population. A prime example is the lack of information on cancer screening in Veterans with SMI, case examples of which were drivers for the request to do this meta-analysis. | Thank you.
5 | The authors note that there were no studies of immunization in the SMI population. The only study that may have included them was from 12 years ago and simply used a composite for all Veterans with any psychiatric diagnosis (excluding SUD), therefore this important area of health inequity has not been addressed for these Veterans. | Thank you. We have included this in the section on Research Gaps.
5 | The tobacco screening and referral information is unfortunately very sparse, given the national focus on smoking cessation. There were insufficient homogeneous studies to conduct a meta-analysis. No studies reported outcomes of treatments for any groups, a wide gap in the research on this important topic. With the limited data, it appears that a disparity may exist for those Veterans without mental illnesses in that they may be less likely to be screened, but screening may not result in referral for care as demonstrated in the only other study to examine this issue. Therefore, little can be said about a high profile program that has mandatory screenings and mandatory referral options for VA clinicians conducting such screenings, and nothing can be said about disparate health outcomes of these efforts (e.g., smoking cessation as an outcome) comparing Veterans with and without mental illnesses. | Thank you for this observation.
5 | Typo on page 51, line 8; “for” should be “of” Typo on page 60, line 40; “a” should be “an” Page 62, end of line 32-33, does not seem complete; hard to make sense of the end of the sentence. Typo page 70, line 19 | We have addressed these editorial issues in the final report.
5 | The authors note that studies addressing the key question 2 regarding the interaction or moderation of health status, mental illness, and key subgroups of interest were virtually lacking. Only one study examined disparities in those with mental illness who lived in rural vs urban areas and that one study included only one health measure (HTN). It should be noted that VA has invested considerable funds into rural access for Veterans with and without mental illnesses, including a major telehealth initiative, and no outcomes papers on these issues in Veterans with mental illnesses were available or adequate for review in this analysis. | Thank you for this observation.
5 | The authors appropriately advise caution with respect to the limited and conflicting results of this analysis. There is a good discussion on the potential limitations in the Clinical and Policy Implications. They are correct in assuming that once someone is identified as belonging to the “SMI” category in VA, that many additional opportunities for screening become available for those patients who remain engaged in care; what is missing in the studies across the board are patients with mental illnesses who are not engaged in, or minimally engaged in, primary and medical subspecialty care. These studies can be done in VA, at least for those who have accessed VA care, but for the most part, such studies are absent. | We agree. Please see the response above about limitations in our eligibility criteria to address people who are not able to access primary care for medical issues.
5 | Typo page 77, line 10. Typo page 77, line 38; “induced” should be “included” | We have addressed these editorial issues in the final report.
5 | Table 9 is an excellent summary of the evidence/research gaps in understanding health disparities in Veterans with mental illnesses. Many of these gaps can be addressed by using existing VA databases to create retrospective cohort studies and cross-sectional studies as suggested in the table. | We agree and have suggested the use of VA data to address these pressing gaps in the literature.
6 | The report is well written and its primary value is to pose further research activity to provide a more accurate reflection of disparities among individuals with mental illness. The problem with this area of research is that there is a broad spectrum of severity of illness in patients with the target conditions of Schizophrenia, BPAD and PTSD. The population is quite heterogeneous and within those diagnoses, disparities may be much more prominent only in the more severe illnesses. This report itself would be improved by making this distinction. It does mention Serious Mental Illness but does not distinguish it from mental illness. | We agree that severity of mental illness is likely an important moderator of effects; however, the existing literature did not provide the necessary granularity in reporting diagnosis or severity to facilitate such analysis.
7 | Reviewer 7 did not have any comments for this section. | Noted