# NEWCASTLE-OTTAWA SCALE CODING MANUAL FOR COHORT STUDIES

The Newcastle-Ottawa Scale quality instrument is scored by awarding a point for each answer that is marked with an asterisk below. Possible total points are 4 points for Selection, 2 points for Comparability, and 3 points for Outcomes.

## SELECTION

1. Representativeness of the Exposed Cohort
  a. Truly representative of the average patient with mental illness (eg, severity of illness, comorbidities) in the community*
  b. Somewhat representative of the average (eg, severity of illness, comorbidities)in the community*
  c. Selected group of users eg HIV+, pregnant, elderly, significant physical disabilities
  d. No description of the derivation of the cohort
2. Selection of the Non-Exposed Cohort
  a. Drawn from the same community as the exposed cohort*
  b. Drawn from a different source
  c. No description of the derivation of the non-exposed cohort
3. Ascertainment of Exposure
  a. Secure record (eg, medical records)*
  b. Structured interview *
  c. Written self-report
  d. No description
4. Demonstration that Outcome of Interest Was Not Present at Start of Study
  a. Yes*
  b. No

## COMPARABILITY

1. Comparability of Cohorts on the Basis of the Design or Analysis
  a. Study controls for SES (or some reasonable proxy of SES), age, race, gender*
  b. Study controls for any additional factor* (this criteria could be modified to indicate specific control for a second important factor)
  c. Inadequate degree of control

## OUTCOME

1. Assessment of Outcome
  a. Independent or blind assessment stated in the paper, or confirmation of the outcome by reference to secure records (x-rays, medical records, etc)*
  b. Record linkage (eg, identified through ICD codes on database records)*
  c. Self-report (ie, no reference to original medical records or x-rays to confirm the outcome)
  d. No description
2. Was Follow-up Long Enough for Outcomes to Occur?
  a. Yes (select an adequate follow up period for outcome of interest)*
  b. No
3. Adequacy of Follow-up of Cohorts
  a. Complete follow-up—all subjects accounted for*
  b. Subjects lost to follow-up unlikely to introduce bias—small number lost (LESS than 20% follow-up, or description provided of those lost)*
  c. Follow-up rate MORE than 20% and no description of those lost
  d. No statement