# SEARCH STRATEGIES

## Database: PubMed

Search date: February 17, 2014

Set # | Search String | Results
#1 | “Mental Disorders”[Mesh:noexp] OR “Bipolar Disorder”[Mesh] OR “Schizophrenia”[Mesh] OR “Stress Disorders, Post-Traumatic”[Mesh] OR “Depressive Disorder, Major”[Mesh] OR “Psychotic Disorders”[Mesh] OR bipolar[tiab] OR schizophrenia[tiab] OR schizophrenic[tiab] OR schizoaffective[tiab] OR mdd[tiab] OR “major depressive disorder”[tiab] OR ptsd[tiab] OR “post traumatic stress disorder”[tiab] OR “posttraumatic stress disorder”[tiab] OR “psychotic disorder”[tiab] OR “psychotic disorders”[tiab] OR “substance abuse”[tiab] OR “drug abuse”[tiab] OR “alcohol abuse”[tiab] OR alcoholism[tiab] OR “alcohol misuse”[tiab] OR “alcohol dependence”[tiab] OR ((heavy[tiab] OR hazardous[tiab] OR harmful[tiab] OR excessive[tiab] OR problem[tiab] OR binge[tiab] OR controlled[tiab] OR risky[tiab] OR “at risk”[tiab] OR “at-risk”[tiab] OR use[tiab]) AND drink*[tiab] AND (Alcohol[tiab] OR “Alcoholic Beverages”[Mesh])) | 393,361
#2 | “Diabetes Mellitus”[Mesh] OR “diabetes”[tiab] OR “Hemoglobin A, Glycosylated”[Mesh] OR “Diagnostic Techniques, Ophthalmological”[Mesh] OR “Blood Glucose”[Mesh] OR “Blood Pressure”[Mesh] OR “Hypertension/prevention and control”[Mesh] OR “diabetes care”[tiab] OR “diabetes control”[tiab] OR hbaic[tiab] OR “hemoglobin a1c”[tiab]OR ldl[tiab] OR “Cholesterol, LDL”[Mesh]OR ldl-c[tiab] OR “glucose control”[tiab] OR “glycemic control”[tiab] OR “foot exam”[tiab] OR “foot exams”[tiab] OR “foot examination”[tiab] OR “foot examinations”[tiab] OR “eye exam”[tiab] OR “eye exams”[tiab] OR “eye examination”[tiab] OR “eye examinations”[tiab] OR retinopathy[tiab] OR retinopathies[tiab] OR nephropathy[tiab] OR nephropathies[tiab] OR “Hypertension”[Mesh] OR “hypertension”[tiab] OR “Myocardial Ischemia”[Mesh] OR “Ischemic heart disease”[tiab] | 1,432,903
#3 | ((“Breast Neoplasms”[Mesh] OR “breast cancer”[tiab] OR “Colorectal Neoplasms”[Mesh] OR “colorectal cancer”[tiab] OR “colon cancer”[tiab] OR “Uterine Cervical Neoplasms”[Mesh] OR “cervical cancer”[tiab]) AND (“Early Detection of Cancer”[Mesh] OR “Mass Screening”[MeSH] OR “Risk Assessment”[Mesh] OR screening[tiab] OR screened[tiab])) OR “Mammography”[Mesh] OR “Sigmoidoscopy”[Mesh] OR “Colonoscopy”[Mesh] OR “Vaginal Smears”[Mesh] OR “Human Papillomavirus DNA Tests”[Mesh] OR mammogram[tiab] OR mammograms[tiab] OR mammography[tiab] OR sigmoidoscopy[tiab] OR “Occult Blood”[Mesh] OR “fecal occult blood test”[tiab] OR FOBT[tiab] OR colonoscopy[tiab] OR “pap smear”[tiab] OR “pap smears”[tiab] OR hpv[tiab] | 127,557
#4 | “Immunization”[Mesh] OR immunization[tiab] OR immunizations[tiab] OR immunize[tiab] OR immunized[tiab] OR vaccinate[tiab] OR vaccinated[tiab] OR vaccination[tiab] OR vaccinations[tiab] | 243,734
#5 | (“Tobacco Use”[Mesh] OR tobacco[tiab])AND (screening[tiab] OR screened[tiab] OR mass screening[mesh]) OR “Tobacco Use Cessation”[Mesh] | 25,163
#6 | #2 OR #3 OR #4 OR #5 | 1,815,682
#7 | #1 AND #6 | 14,200
#8 | “delivery of health care”[MeSH Terms:noexp] OR “healthcare disparities”[MeSH Terms] OR “health behavior”[MeSH Terms] OR “health knowledge, attitudes, practice”[MeSH Terms] OR “health services accessibility”[MeSH Terms] OR “Health Status”[MeSH] OR “health services needs and demand”[MeSH] OR “patient acceptance of health care”[MeSH Terms] OR “patient selection”[MeSH Terms] OR “quality of health care”[MeSH:noexp] OR “Outcome and Process Assessment (Health Care)”[Mesh] OR “Quality Indicators, Health Care”[Mesh] OR “Quality Assurance, Health Care”[Mesh] OR “socioeconomic factors”[MeSH] OR socioeconomic factor[TIAB] OR socioeconomic factors[TIAB] OR disparity[tiab] OR disparities[tiab] OR inequity[tiab] OR inequities[tiab] OR inequitable[tiab] OR inequality[tiab] OR inequalities[tiab]OR undertreat[tiab] OR undertreated[tiab] OR undertreatment[tiab] | 1,673,781
#9 | #7 AND #8 | 2,480
#10 | #9 NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 2,294
#11 | #10, Limits: 1994 – present, English | 1,923

## Database: Embase

Search date: February 19, 2014

Set # | Search String | Results
#1 | ‘mental disease’/de OR ‘bipolar disorder’/exp OR ‘posttraumatic stress disorder’/exp OR ‘major depression’/exp OR ‘psychosis’/exp OR bipolar:ab,ti OR schizophrenia:ab,ti OR schizophrenic:ab,ti OR schizoaffective:ab,ti OR mdd:ab,ti OR ‘major depressive disorder’:ab,ti OR ptsd:ab,ti OR ‘post traumatic stress disorder’:ab,ti OR ‘posttraumatic stress disorder’:ab,ti OR ‘psychotic disorder’:ab,ti OR ‘psychotic disorders’:ab,ti OR ‘substance abuse’:ab,ti OR ‘drug abuse’:ab,ti OR ‘alcohol abuse’:ab,ti OR alcoholism:ab,ti OR ‘alcohol misuse’:ab,ti OR ‘alcohol dependence’:ab,ti OR ((heavy:ab,ti OR hazardous:ab,ti OR harmful:ab,ti OR excessive:ab,ti OR problem:ab,ti OR binge:ab,ti OR controlled:ab,ti OR risky:ab,ti OR ‘at risk’:ab,ti OR ‘at-risk’:ab,ti OR use:ab,ti) AND drink*:ab,ti AND (Alcohol:ab,ti OR ‘alcoholic beverage’/exp)) | 576,664
#2 | ‘diabetes mellitus’/exp OR ‘diabetes’:ab,ti OR ‘hemoglobin A1c’/exp OR ‘eye examination’/exp OR ‘glucose blood level’/exp OR ‘blood glucose monitoring’/exp OR ‘blood pressure’/exp OR ‘blood pressure monitoring’/exp OR ‘diabetes care’:ab,ti OR ‘diabetes control’:ab,ti OR hbaic:ab,ti OR ‘hemoglobin a1c’:ab,ti OR ldl:ab,ti OR ‘low density lipoprotein cholesterol’/exp OR ldl-c:ab,ti OR ‘glucose control’:ab,ti OR ‘glycemic control’:ab,ti OR ‘foot exam’:ab,ti OR ‘foot exams’:ab,ti OR ‘foot examination’:ab,ti OR ‘foot examinations’:ab,ti OR ‘eye exam’:ab,ti OR ‘eye exams’:ab,ti OR ‘eye examination’:ab,ti OR ‘eye examinations’:ab,ti OR retinopathy:ab,ti OR retinopathies:ab,ti OR nephropathy:ab,ti OR nephropathies:ab,ti OR ‘hypertension’/exp OR ‘hypertension’:ab,ti OR ‘heart muscle ischemia’/exp OR ‘Ischemic heart disease’:ab,ti | 1,655,117
#3 | ((‘breast cancer’/exp OR ‘breast cancer’:ab,ti OR ‘colon tumor’/exp OR ‘colorectal cancer’:ab,ti OR ‘colon cancer’:ab,ti OR ‘uterine cervix cancer’/exp OR ‘cervical cancer’:ab,ti) AND (‘early diagnosis’/exp OR ‘mass screening’/exp OR ‘risk assessment’/exp OR screening:ab,ti OR screened:ab,ti)) OR ‘mammography’/exp OR ‘sigmoidoscopy’/exp OR ‘colonoscopy’/exp OR ‘Papanicolaou test’/exp OR ‘Human papillomavirus DNA test’/exp OR mammogram:ab,ti OR mammograms:ab,ti OR mammography:ab,ti OR sigmoidoscopy:ab,ti OR ‘occult blood’/exp OR ‘fecal occult blood test’:ab,ti OR FOBT:ab,ti OR colonoscopy:ab,ti OR ‘pap smear’:ab,ti OR ‘pap smears’:ab,ti OR hpv:ab,ti | 183,910
#4 | ‘immunization’/exp OR immunization:ab,ti OR immunizations:ab,ti OR immunize:ab,ti OR immunized:ab,ti OR vaccinate:ab,ti OR vaccinated:ab,ti OR vaccination:ab,ti OR vaccinations:ab,ti | 311,311
#5 | ((‘tobacco use’/exp OR tobacco:ab,ti) AND (screening:ab,ti OR screened:ab,ti OR ‘screening’/exp)) OR ‘smoking cessation’/exp | 48,342
#6 | #2 OR #3 OR #4 OR #5 | 2,168,928
#7 | #1 AND #6 | 34,010
#8 | ‘health care delivery’/de OR ‘health status’/exp OR ‘health behavior’/exp OR ‘patient abandonment’/exp OR ‘health service’/de OR ‘patient attitude’/exp OR ‘patient selection’/exp OR ‘health care quality’/de OR ‘clinical indicator’/exp OR ‘outcome assessment’/exp OR ‘socioeconomics’/exp OR ‘socioeconomic factor’:ab,ti OR ‘socioeconomic factors’:ab,ti OR disparity:ab,ti OR disparities:ab,ti OR inequity:ab,ti OR inequities:ab,ti OR inequitable:ab,ti OR inequality:ab,ti OR inequalities:ab,ti OR undertreat:ab,ti OR undertreated:ab,ti OR undertreatment:ab,ti | 1,323,993
#9 | #7 AND #8 | 7,479
#10 | #9 AND [humans]/lim AND [english]/lim NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp) | 5,932
#11 | #10 AND [embase]/lim NOT [medline]/lim | 1,642
#11 | #10, Limits: 1994 – present | 1,635

## Database: PsycINFO

Search date: February 21, 2014

Set # | Search String | Results
S1 | MM “Mental Disorders” OR DE “Affective Disorders” OR DE “Bipolar Disorder” OR DE “Schizophrenia” OR DE “Schizoaffective Disorder” OR DE “Posttraumatic Stress Disorder” OR DE “Major Depression” OR DE “Psychosis” OR bipolar OR schizophrenia OR schizophrenic OR schizoaffective OR mdd OR “major depressive disorder” OR ptsd OR “post traumatic stress disorder” OR “posttraumatic stress disorder” OR “psychotic disorder” OR “psychotic disorders” | 286,723
S2 | DE “Drug Abuse” OR DE “Drug Dependency” OR DE “Inhalant Abuse” OR DE “Polydrug Abuse” OR DE “Drug Addiction” OR DE “Heroin Addiction” OR DE “Alcoholism” OR DE “Alcoholic Psychosis” OR DE “Alcoholic Beverages” OR DE “Alcohol Drinking Patterns” OR DE “Alcohol Abuse” OR DE “Alcohol Intoxication” OR DE “Social Drinking” OR “substance abuse” OR “drug abuse” OR “alcohol abuse” OR alcoholism OR “alcohol misuse” OR “alcohol dependence” | 137,933
S3 | S1 OR S2 | 406,813
S4 | DE “Diabetes” OR DE “Diabetes Insipidus” OR DE “Diabetes Mellitus” OR diabetes OR DE “Glucose” OR DE “Blood Sugar” OR DE “Blood Pressure” OR DE “Diastolic Pressure” OR DE “Systolic Pressure” OR “diabetes care” OR “diabetes control” OR hbaic OR “hemoglobin a1c” OR “glucose control” OR “glycemic control” OR “foot exam” OR “foot exams” OR “foot examination” OR “foot examinations” OR “eye exam” OR “eye exams” OR “eye examination” OR “eye examinations” OR retinopathy OR retinopathies OR nephropathy OR nephropathies | 27,949
S5 | S3 AND S4 | 3,936
S6 | DE “Cardiovascular Disorders” OR “Hypertension” OR “Myocardial Ischemia” OR “Ischemic heart disease” OR ldl OR DE “Cholesterol” OR ldl-c | 19,873
S7 | S3 AND S6 | 3,177
S8 | DE “Cancer Screening” OR DE “Mammography” OR mammogram OR mammograms OR mammography OR Colonoscopy OR Sigmoidoscopy OR FOBT OR “fecal occult blood test” OR “Vaginal Smears” OR “pap smear” OR “pap smears” OR hpv | 4,631
S9 | S3 AND S8 | 112
S10 | DE “Immunization” immunization OR immunizations OR immunize OR immunized OR vaccinate OR vaccinated OR vaccination OR vaccinations | 4,580
S11 | S3 AND S10 | 265
S12 | ((DE “Nicotine” OR DE “Tobacco Smoking” OR DE “Smokeless Tobacco” OR cigarettes OR smoking) AND (DE “Screening” OR screening OR screened)) OR DE “Smoking Cessation” | 9,781
S13 | S3 AND S12 | 2,662
S14 | S5 OR S7 OR S9 OR S11 OR S13 | 9,216
S15 | DE “Health Disparities” OR DE “Health Care Delivery” OR DE “Health Care Seeking Behavior” OR DE “Health Care Utilization” OR DE “Health Service Needs” OR DE “Quality of Care” OR DE “Treatment Barriers” OR DE “Health Behavior” OR DE “Health Knowledge” OR DE “Health Literacy” OR DE “Health Care Services” OR DE “Continuum of Care” OR DE “Mental Health Services” OR DE “Primary Health Care” OR “socioeconomic factor” OR “socioeconomic factors” OR disparity OR disparities OR inequity OR inequities OR inequitable OR inequality OR inequalities OR undertreat OR undertreated OR “under treatment” | 137,042
S16 | S14 AND S15 Limiters - Publication Year: 1994-2014; English; Language: English; Age Groups: Adulthood (18 yrs & older); Population Group: Human; Exclude Dissertations Search modes - Find all my search terms | 490

## Database: The Cochrane Library

Search date: February 21, 2014

Set # | Search String | Results
#1 | mental disease:ti,ab,kw (Word variations have been searched) | 592
#2 | mental illness:ti,ab,kw (Word variations have been searched) | 952
#3 | bipolar affective disorder:ti,ab,kw (Word variations have been searched) | 83
#4 | schizophrenia:ti,ab,kw (Word variations have been searched) | 8,445
#5 | schizophrenic disorder:ti,ab,kw (Word variations have been searched) | 75
#6 | schizoaffective:ti,ab,kw (Word variations have been searched) | 727
#7 | major depressive disorder:ti,ab,kw (Word variations have been searched) | 2,496
#8 | post traumatic stress disorder:ti,ab,kw (Word variations have been searched) | 373
#9 | psychotic disorder:ti,ab,kw (Word variations have been searched) | 1,534
#10 | [mh “Mental Disorders” [mj]] or [mh “Bipolar Disorder”] or [mh Schizophrenia] or [mh “Stress Disorders, Post-Traumatic”] or [mh “Depressive Disorder, Major”] or [mh “Psychotic Disorders”] | 10,344
#11 | {or #1-#10} in Cochrane Reviews (Reviews only) | 247
#12 | [mh “health knowledge, attitudes, practice”] or [mh “health services accessibility”] or [mh “Health Status”] or [mh “health services needs and demand”] or [mh “patient acceptance of health care”] or [mh “patient selection”] or [mh “quality of health care” [mj]] or [mh “Outcome and Process Assessment (Health Care)”] or [mh “Quality Indicators, Health Care”] or [mh “Quality Assurance, Health Care”] or [mh “socioeconomic factors”] or “socioeconomic factor” or “socioeconomic factors” or disparity or disparities or inequity or inequities or inequitable or inequality or inequalities or undertreat or undertreated or “under treatment” or “health status”:ti,ab,kw or “health services research”:ti,ab,kw or “primary care”:ti,ab,kw | 129,822
#13 | #11 and #12 | 39
#14 | [mh “Diabetes Mellitus”] or diabetes or [mh “Hemoglobin A, Glycosylated”] or [mh “Diagnostic Techniques, Ophthalmological”] or [mh “Blood Glucose”] or [mh “Blood Pressure”] or “diabetes care” or “diabetes control” or hbaic or “hemoglobin a1c” or ldl or [mh “Cholesterol, LDL”] or ldl-c or “glucose control” or “glycemic control” or “foot exam” or “foot exams” or “foot examination” or “foot examinations” or “eye exam” or “eye exams” or “eye examination” or “eye examinations” or retinopathy or retinopathies or nephropathy or nephropathies or [mh Hypertension] or “hypertension” or [mh “Myocardial Ischemia”] or “Ischemic heart disease” | 104,682
#15 | [mh “Breast Neoplasms”] or “breast cancer” or [mh “Colorectal Neoplasms”] or “colorectal cancer” or “colon cancer” or [mh “Uterine Cervical Neoplasms”] or “cervical cancer” or [mh “Early Detection of Cancer”] or [mh Mammography] or [mh Sigmoidoscopy] or [mh Colonoscopy] or [mh “Vaginal Smears”] or [mh “Human Papillomavirus DNA Tests”] or mammogram or mammograms or mammography or sigmoidoscopy or [mh “Occult Blood”] or “fecal occult blood test” or FOBT or colonoscopy or “pap smear” or “pap smears” or hpv | 27,880
#16 | [mh Immunization] or immunization or immunizations or immunize or immunized or vaccinate or vaccinated or vaccination or vaccinations | 9,917
#17 | [mh “Tobacco Use”] or tobacco or [mh “Tobacco Use Cessation”] or cigarette or cigarettes or smoking or nicotine | 17,248
#18 | #13 and {or #14-#17} from 1994 to 2014 | 22