# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question #1 What are the current usage patterns of directly acting antivirals and of IL-28B patient genotyping in the VA health system? And how do these patterns differ by VISN?

Between July 2011 and the end of June 2012, nearly 3,000 people initiated DAA treatment, with approximately 80% using on-formulary boceprevir (Boceprevir N=2,366, Telaprevir N=501). During this same period, 2,171 individuals had an IL-28B test. There was heterogeneity in number of people taking up DAA therapies and IL-28B testing across VISNs

VISNs differed in the rates of use of IL-28B testing in patients who were prescribed DAA medications, with a national average just above 10 percent. VISN 22 had the greatest number of IL-28B tests, while VISNs 8, 16, and 21 had the greatest number of patients initiating DAA therapy. In some VISNs there were more patients initiating DAA therapy than getting IL-28B tests, while in other VISNs the reverse was true. Seven VISNs used testing in five percent or less of patients receiving DAA, whereas three VISNs used testing on 30 percent or more of these patients.

The median length of boceprevir treatments was just under 28 weeks. Of those who initiated boceprevir, 89% got to 8 weeks, 81% to 12 weeks, 76% to 16 weeks, and 29% to 32 weeks. Telaprevir episodes were much shorter per its therapeutic protocol. Median length of telaprevir treatments was between 12 and 16 weeks. None lasted beyond 28 weeks.

### Key Question #2 What will be the health impacts of using either of two available directly acting antivirals combined with pegylated interferon and ribavirin (triple therapy)?

When compared to standard therapy, universal triple therapy was likely to reduce annual cases of decompensated cirrhosis by 10–29 (current uptake: 10; doubled uptake: 29; quadrupled uptake: 50). When comparing universal triple therapy to standard therapy, annual cases of hepatocellular carcinoma were likely to be reduced by 5–16 (current: 5; doubled: 16; quadrupled: 27). Finally, when comparing universal triple therapy to standard therapy, annual numbers of liver transplants are likely to be reduced by 0–1 (current: 0; doubled: 1; quadrupled: 2). Consequently, annual quality adjusted life years (QALYs) increased by 148–213 (current: 148; doubled: 213; quadrupled: 322).

### Key Question #3 How will be the magnitudes of the health impacts measured in Key Question #2 change if IL-28B patient genotyping is used to offer triple therapy to those less likely to benefit from two-drug pegylated interferon + ribavirin?

Comparing IL-28B guided therapy to standard two-drug therapy, annual cases of decompensated cirrhosis are likely to be reduced by 8–26 (current uptake: 8; doubled uptake: 26; quadrupled uptake: 45), annual cases of hepatocellular carcinoma are likely to be reduced by 4–14 (current: 4; doubled: 14; quadrupled: 25), and annual numbers of liver transplants are likely to be reduced by 0–1 (current: 0; doubled: 1; quadrupled: 2). Consequently, annual QALYs increased by 110–145 (current: 110; doubled: 145; quadrupled: 225).

### Key Question #4 What will be the cost and resource use patterns when using either triple therapy or IL-28B-guided triple therapy?

Depending on uptake patterns, increased total expenditures for HCV treatment and care for individuals with GT1 HCV relative to standard two-drug therapy will likely be $32-$100 million annually. At the current uptake rate of 2 percent per year, universal triple drug therapy would be expected to cost $43 million more, while IL-28B guided therapy would be expected to cost $32 million more, compared to standard two-drug therapy.

## LIMITATIONS

Key uncertainties remain as with all studies and especially in the case of rapid, preliminary analyses. Below we summarize a number of these.

The IL-28B genotype distribution in the VA population has not yet been described. Our study uses race-specific IL-28B genotype distributions observed in other studies. The VA specific distribution might be different from that observed in other studies.

The liver fibrosis distribution in the VA population is based on diagnostic codes in administrative datasets. We did not have the more definitive results from liver biopsies, but this omission may not be very important, as biopsies are not performed in most persons with chronic HCV infection. Laboratory data can be used to estimate the stage of their fibrosis and may provide more accurate information on the distribution of fibrosis in future studies.

The modeling analysis focused on VA as a whole. It is clear from the preliminary VA administrative data analyses that there is heterogeneity in the adoption of DAAs and IL-28B between VISNs. We had insufficient information to project potential differences in uptake in these treatments by VISN. Furthermore, there are other patient, provider, and facility characteristics that may play a role in determining use of these new technologies and additionally, depending on the results from IL-28B testing may also play a role in determining subsequent clinical actions and patient behaviors. Information in this area could help to further refine the analyses presented here.

The modeling analysis is confined to treatment-naïve, HCV mono-infected individuals as evidence of effectiveness for those co-infected with HIV is only beginning to emerge and utilization data needed to support VA-specific analyses stratified by co-infection status are also needed. Analyses like those presented here for individuals with previous experience of HCV treatment would be important to conduct, though are complicated by a number of issues including fewer data on effectiveness, various types of treatment failures, and reasons for failure including lack of adherence to medication regimen versus non-response to appropriately taken medications.

The modeling analysis considers three strategies including one strategy where IL-28B genotyping is used to determine triple therapy treatment versus standard therapy treatment. IL-28B genotype along with other predictive markers for treatment response are an exciting new avenue.42–44 Our analysis considers one such approach, though others may also be possible. Ultimately, all such approaches attempt to optimize over treatment response, side-effects, and costs in achieving best outcomes for individual patients.

More generally, it is unclear how uptake rates may change beyond those observed in the first year of VA administrative data. Newer therapies and technologies are in clinical trials and could potentially represent even more attractive options for clinicians and Veterans, and may supplant the treatments we considered. Conversely physician education or other diffusion of information processes could increase uptake rates over time. Uncertainties in uptake scenarios can be reduced by periodically reevaluating the VA administrative data.

## RECOMMENDATIONS FOR FUTURE RESEARCH

Therapy for HCV is evolving rapidly and important questions remain unanswered. As clinicians use currently approved DAAs more extensively and additional DAAs become available, future research should evaluate the health and economic outcomes that result from use of these therapies. This research should evaluate: practice patterns, including variations in care among VISNs; patient selection for treatment; effectiveness of DAAs in Veterans (in contrast to efficacy as measured in randomized trials) and in specific Veteran populations, such as patients with substance use disorders; utilization and costs from treatment and complications of HCV infection (e.g., costs); impact on specific VA budgets (pharmacy care, specialty care); cost-effectiveness of treatment and genetic testing; and barriers to diffusion of high-value therapies.

## CONCLUSIONS

Approximately 3,000 Veterans initiated care with DAAs since their approval, with about 80% receiving boceprevir. Uptake of DAAs and use of IL-28B testing varies substantially among VISNs, unadjusted for the number of patients who are eligible for treatment. Our model-based analyses indicate that use of triple therapy results in better outcomes than standard therapy, but at increased costs. Use of IL-28B to select patients for triple therapy results in modest reductions in anticipated health benefits and costs. Assessment of the cost effectiveness of use of IL-28B guided therapy or universal therapy with DAAs will require projection of long-term health outcomes and costs.