# RESULTS

## RESULTS USED TO INFORM THE MODEL

Table 1 below shows the number of sources with information relevant to various parts of the topic.

Table 1 Number of Sources Identified for Each Model Attribute/Area

Attribute | # of Sources
Age | 28
Sex | 27
Race/ethnicity | 25
Fibrosis stage | 11
HCV genotype | 15
Liver transplant | 2
Liver cancer | 3
Mortality | 4
HCV clearance | 4
Treatment eligibility | 10
Treatment uptake | 9
Treatment completion | 11
Treatment effectiveness | 13
Side-effects | 4
HCV care costs | 1
Drug costs | 1
Side-effect costs | 1
Advanced liver disease costs | 1
Quality of life | 8

We now describe the information from the published studies within the sources noted in the table above. Many studies describe the demographic and health characteristics of Veterans with chronic HCV infections. The mean age of individuals with chronic HCV infections is between 45–55 years in most studies with the majority in the low to mid 50s.2–26 Most individuals with chronic HCV in VA are male, with study means falling between 90–100% with the majority at 97%.2–4,6,7,9–19,21–25,27 Race/ethnicity reports tend to be complete in smaller clinical studies with substantial portions marked as missing or unknown in very large registry and administrative studies. Even so, if one looks at the proportion of White to African American individuals among those whose race/ethnicity is reported, there is reasonable stability across studies with a ratio of between 2.0:1 and 2.5:1 being common – hence for the analysis we assume that of African American and White individuals, the percentage that were White was assumed to be 69%.2–4,6,11,13–16,18–21,23–28 HCV genotype is reported in a number of studies, though often not all individuals in the study have their HCV infection genotyped and sometimes genotypes 1 and 4 are grouped together as are genotypes 2 and 3. In these studies, typically 70–85% of chronic HCV infections are genotype 1.^2,5,7,10,11,13,15,17,19,22,24–27^ Liver fibrosis stage distribution is important information that is not reported in many studies, with F0-F2 often grouped together and F3-F4 grouped together. In some studies, only F4 and decompensated cirrhosis are reported. Typically the F2 and F3 fibrosis stages are the most common in these studies. 6,7,10,13,17,19,24–27,29 Clearance rates of chronic HCV infection are reported in one study.20 These data inputs to the model are summarized in Table 2, below.

Table 2 Demographic Characteristics Assumed for VA HCV GT1 Population

Model Input | Value
Age (years) | 55
Sex
Male | 97%
Female | 3%
Race
White | 69%
African American | 31%
Fibrosis Distribution (see below for alternatives)
F0 | 8%
F1 | 25%
F2 | 33%
F3 | 20%
F4 | 14%

Fewer studies provide detailed data on advanced liver disease. Few studies report data on liver transplantation, though a review of liver transplant outcomes in African Americans includes information on African American Veterans.30 Likewise, there is relatively little information on hepatocellular carcinoma in the chronic HCV infected Veterans.29–31 These data inputs to the model are summarized in Table 3, below.

Table 3 Transplantation for Advanced Liver Disease related to HCV

Model Input | Value | Sources/Notes
Rate of liver transplantation for individuals with decompensated cirrhosis (chronic genotype 1 HCV who are treatment eligible) (# per 100,000 person years) | 2,500 | Based on preliminary analyses of VA administrative data for 2010 prepared by HERC, it appears that approximately 0.5% have liver transplants within VA itself. However, these data rely on a very small sample size and only 6 months of follow-up on average. Specifically, among 16,234 VA patients in FY10, 79 (.49%) had a liver transplant during the year. This count includes transplants provided by non- VA providers if these were sponsored by VA. Given that the model tracks post-transplant care within VA even if transplants themselves occur outside VA, we assume a higher rate so as not to undercount costs in the model.
Rate of liver transplantation for individuals with HCC (chronic genotype 1 HCV who are treatment eligible) (# per 100,000 person years) | 8,000 | Based on preliminary analyses of VA administrative data for 2010 prepared by HERC, it appears that approximately 0.5% have liver transplants within VA itself. However, these data rely on a very small sample size and only 6 months of follow-up on average. Specifically, among 2,883 VA patients with HCC in FY10, 42 (1.5%) had a liver transplant. This count includes transplants provided by non- VA providers if these were sponsored by VA. Given that the model tracks post-transplant care within VA even if transplants themselves occur outside VA, we assume a higher rate so as not to undercount costs in the model.

A number of studies provide information on HCV treatment-related parameters within VA. Consistent information on the proportion of Veterans who are treatment eligible is less available as the definition of treatment eligibility differs between studies and between clinician assessment as well as official VA guidance over time in this regard. In general, treatment eligibility ranges from approximately 30–55% and is most commonly in the 40–45% range,2,4,7,15–18,27,28,32 though this may be somewhat lower in the VA population if the studies were conducted in populations who are more likely to be eligible for treatment. Studies on treatment uptake also are less straightforward to compare as some report uptake among those who are treatment eligible and some report on uptake among all participants. Furthermore, uptake is often reported as a cumulative percentage with different lengths of follow-up. Long-term uptake among treatment eligible individuals ranges from approximately 20–50% in studies with 30–35% being the most common.2,4,7,10,15,17,18,27 For similar reasons, treatment completion rates reported in various studies are difficult to compare, 2,4,7,15,19,24,26–28,33,34 as are treatment success rates.2,6,7,10,11,15,19,24,26–28,30,32,33 Given these challenges, we describe how we estimate treatment completion and success rates for the VA population we model below.

HCV treatment completion and success rate information for the VA population, especially for very recently introduced triple therapy that includes a DAA, is not readily available. We estimated these parameters using the following methods for both standard two-drug treatment and triple therapy. For both standard treatment and triple therapy, we used the race/ethnicity distributions derived as described in the preceding paragraphs. Because, treatment effectiveness was predicated on IL-28B genotype, we used the distribution of CC versus non-CC (CT and TT) IL-28B genotypes by race/ethnicity reported in Thompson (2010).34

For standard two-drug treatment, overall rates of treatment completion were similar across multiple studies within VA.15,24,33 Because the data from Beste (2010) provides information on which individuals quit due to treatment failure versus an unspecified reason, we used this study in particular to estimate the overall rate of treatment non-completion for a reason other than treatment failure.33 Butt (2010) showed that African Americans were 10% less likely to complete treatment than individuals of other races, so we calculated race-specific treatment non-completion rates.4 Beste (2010) also identified the overall proportion of patients who terminated treatment due to treatment failure at 12 and 24 weeks.33 We estimated the race- and IL-28B- genotype stratified relative risks of treatment failure at 12 and 24 weeks based on Thompson (2010).34 Using these new race- and IL-28B genotype-stratified probabilities of treatment failure at 12 and 24 weeks, we computed the race- and IL-28B genotype stratified rates of SVR for patients who completed 48 weeks of treatment such that these SVR rates satisfied race-specific SVR rate ratios for CC to non-CC types (Thompson 2010) and the overall intent to treat SVR rate observed in Kramer (2012) (i.e., 27% in non-African Americans and 15.8% in African Americans).15 These data inputs to the model are summarized in Table 4, below.

Table 4 Treatment Parameters Estimates for the VA HCV GT1 Population

Model Input | Value for Whites | Value for African Americans
Treatment dropout rate (# per 100,000 person years) | 37,040 | 48,534
Standard Two-Drug Therapy Parameters
Early Virologic Response (EVR) at 12 weeks
CC genotype | 98% | 97%
Non-CC genotype | 91% | 86%
Continue treatment beyond 24 weeks (conditional on EVR at 12 weeks)
CC genotype | 97% | 89%
Non-CC genotype | 86% | 82%
Sustained Virologic Response (SVR) (conditional on 48 weeks of treatment)
CC genotype | 60% | 60%
Non-CC genotype | 34% | 27%
Triple Therapy Parameters
No virologic failure at 12 weeks
CC genotype | 98% | 97%
Non-CC genotype | 91% | 86%
No virologic failure at 24 weeks (conditional on no failure at 12 weeks)
CC genotype | 62% | 48%
Non-CC genotype | 43% | 48%
No virologic failure at 48 weeks (conditional on no failure at 12 weeks)
CC genotype | 28% | 38%
Non-CC genotype | 42% | 38%
Sustained virologic response given 24 weeks of treatment
CC genotype | 98% | 95%
Non-CC genotype | 95% | 89%
Sustained virologic response given 48 weeks of treatment
CC genotype | 75% | 70%
Non-CC genotype | 65% | 60%

For triple therapy, we used a very similar process to that for standard two-drug therapy. Importantly, no studies report on treatment completion rates for triple therapy in VA since these treatments have only recently been introduced. The assumptions we used, therefore, were less VA-specific than for standard two-drug therapy and more closely resembled our previously published analysis.1 We assumed that patients do not complete treatment for reasons other than treatment failure at the same rate whether they are receiving standard or triple therapy, using standard therapy VA-specific discontinuation rates described above. We assumed that the race- and IL-28B-genotype specific 12 week treatment failure rate was the same for patients receiving standard or triple therapy, also as described above. These small changes in assumptions, while maintaining all of other assumptions from the prior analysis,1 resulted in triple therapy intent to treat SVR rates of 48.9% in non-African Americans and 37.3% in African Americans. These data inputs to the model are summarized in Table 4, below.

A number of studies report quality-of-life for Veterans with chronic HCV infections both for those not on treatment as well as those while on treatment (including rates of side-effects).19,21,22,27,28,35–40

Notably, very limited information appears in the published literature on the cost of HCV treatment and care for Veterans in VA. For costs we relied on prior communications with the Office of Pharmacy Benefits Management as well as preliminary analyses performed by HERC. Additionally, both for costs and other information, we relied on the VA State of Care report on HCV.1 The cost data included in the model are summarized in Table 5, below.

Table 5 VA-specific Cost Inputs

Cost Type | Amount | Sources/Notes
Cost of Peg-RIB 48 weeks and care/monitoring during that time^*^ | $15,281 | Peg-RIB costs $9,120 to which we add costs of care during the 48 weeks of treatment of $6,161 (assuming a full 48 weeks) assumed to be 1.5 times the costs of HCV care prior to treatment success to account for other monitoring, etc.
Additional Cost of Boceprevir (24 weeks) (to be added to the Cost of Peg-RIB 48 weeks above) | $18,753 | Assumed Boceprevir (provisional) FSS price is $3,125.49 per 28 day supply
Additional Cost of Telaprevir (12 weeks) (to be added to the Cost of Peg-RIB 48 weeks above) | $36,828 | Assumed Telaprevir (provisional) FSS price is $12,276.10 per 28 day supply
Average adverse events costs 2 drug therapy | $1,920
Average adverse events costs 3 drug therapies | $2,586 | The mix of adverse events is different for Boceprevir and Telaprevir but the average costs (likelihood times cost of dealing with the side- effects, summed over all side-effects) for both drugs have been observed to be quite similar (see for example, Stephens, et. al. AASLD poster, 38).
Annual HCV care (w/o Peg- RIB or other treatment costs) | $4,450 | HERC preliminary analysis of 2010 data: Since this is just care that is related to HCV and liver disease we take the difference of the total cost of care for people with uncomplicated chronic HCV ($11,486) and subtract the average cost of care for people in VA ($7,036)
Annual post-successful treatment HCV care costs | $2,225 | HERC preliminary analysis of 2010 data, per note above: We assume that this care is roughly 50% of the cost of care prior to achieving treatment success as seen in studies not specific to VA HCV patient populations.
Annual decompensated cirrhosis care costs (w/o Peg- RIB or other Tx) | $13,093 | HERC preliminary analysis of 2010 data, per note above: We subtract from the costs for those with decompensated cirrhosis ($20,129) the average costs of care for people in VA ($7,036).
Annual HCC costs (w/o Peg- RIB or other Tx) | $71,954 | HERC preliminary analysis of 2010 data suggests an annual cost of $33,096 among all individuals, including those who died and did not complete full year of treatment. Since our cost is conditional on survival (model cycle length much shorter than 1 year), we used a VA report and other data that suggest a roughly 15% 3-year survival. (http://www.hepatitis.va.gov/provider/reviews/HCC.asp and Surveillance, Epidemiology and End Results (SEER)) which implies that the cost should be multiplied by [1.00/0.46], implying the cost of $71,954.
Year of Liver Transplant cost of care | $152,313 | HERC preliminary analysis of 2010 data, adjusted for censoring of people who die and do not complete full year of treatment: $134,036 (using 1.00/0.88 again as the survival multiplier as above) Other sources suggest that costs are closer to: $250,000 but may include the transplant itself as well as a 7-day hospital stay. Still other sources suggest $150,000 – $250,000 range (http://www.hepatitis.va.gov/pdf/feedback-forum.pdf from 2007)
Years post Liver Transplant cost of care | $32,903 | HERC preliminary analysis of 2010 data, adjusted for censoring of people who die and do not complete full year of treatment: $31,587 (here we use a 1.00/0.96 survival multiplier) Other sources suggest $12,000 as the annual medication cost alone (http://www.hepatitis.va.gov/patient/complications/transplant-basics.asp)

* Note: For the costs of treatment using response guided algorithms (i.e., triple therapies), costs are scaled for early stopping due to Early Virologic Response or failure to achieve sufficient reductions per response guided therapy in the model itself.

We defined a representative cohort of chronic HCV GT1 infected individuals in VA based on published studies of VA HCV populations and other VA-specific documents and data which are described in the results. The cohort’s age is 55 years with 97% male, 69% white, and 31% African American. These characteristics as well as the liver fibrosis distribution assumed are shown in Table 2 above.

### Treatment-eligible Patient Population

The total population of chronic HCV infected Veterans is approximately 189,065 according to the VA’s State of Care 2010 report. The report also notes that this number has stayed stable over the preceding 5 years. Of these, based on the literature review, we assume that approximately 80% are genotype 1 HCV infections – the major genotype with the lowest overall response rate to standard two-drug therapy, for which DAAs appear to offer the greatest benefit, and in which they have been best studied to date. Of these individuals, again based on the literature review, approximately 45% are treatment-eligible. Finally, since the analysis focuses on treatment-naïve individuals and based on the State of Care 2010 report as well as the published literature, we assume that approximately 70% of individuals have not been treated previously.

8,000≅189,065*0.80*0.45*0.70

Based on these calculations, the analysis uses an estimate of approximately 48,000 GT1 chronic HCV-infected, treatment-eligible, treatment-naïve Veterans for determining total costs and health benefits.

### Uptake Scenarios

The analysis considered multiple uptake scenarios. In all scenarios, the comparator was standard two-drug therapy offered to all treatment-eligible patients with the assumption that 2% of this group took up therapy annually over the 5 year window considered in the analysis. Uptake scenarios considered the effects of DAAs possibly combined with IL-28B genotyping at three different levels of uptake:

- Approximately 2% of treatment-eligible chronic HCV GT1 infected Veterans take-up HCV treatment each year, similar to uptake rates for standard two-drug therapy
- Approximately 4% each year, double the uptake rates for standard two-drug therapy – slightly above those actually observed in VA towards the latter half of FY2008, based on the preliminary analyses reported below (Figure 2)
- Approximately 8% each year, quadruple the uptake rates for standard two-drug therapy

Figure 2 Cumulative Proportion of Treatment-eligible, Chronic HCV Individuals Taking Up Therapy

Multiple uptake scenarios were explored because future uptake is highly uncertain. There is little experience with DAAs and IL-28B genotyping as they have only recently become available in VA. The effect of newer treatments and technologies currently in clinical testing contributes to this uncertainty. Figure 2 below compares historical rates of uptake of standard two drug therapy to the uptake scenarios we consider for DAA strategies.

### Combining Uptake Scenarios with the Treatment-eligible Population for Analyses

Table 6 estimates the number of individuals initiating treatment under each uptake scenario. The analyses consider what would happen over the next five years if the strategy was switched from standard two-drug therapy to each of the two other alternatives. Separate estimates are made for each strategy under each of the three uptake scenarios.

Table 6 Treatment Eligibility and Uptake over 5 Years (number of Veterans)

Veterans with HCV | 189,065
Veterans with GT1 HCV | 106,667
Veterans with GT1 HCV eligible for treatment | 48,000
Current uptake rate (2%/year) | 15,495
Doubled uptake rate (4%/year) | 26,702
Quadrupled update rate (8%/year) | 36,609

## KEY QUESTION #1 What are the current usage patterns of directly acting antivirals and of IL-28B patient genotyping in the VA health system? And how do these patterns differ by VISN?

### Sub-question 1.1 How many people initiated DAAs during 07/1/11–06/30/12? How did this differ across VISNs? How has this changed since the introduction of DAAs into VA?

Between July 2011 and June 2012 nearly 3,000 people initiated DAA treatment, with approximately 80% using on-formulary boceprevir (Boceprevir N=2,366, Telaprevir N=501). There was heterogeneity in the number of people taking up DAA therapies across VISNs (see Figure 3). Part of this difference must be attributed to differences in the number of treatment-eligible chronic HCV-infected Veterans in each VISN. Uptake of DAAs increased since July 2011, but seems to have stabilized at approximately 300 new people initiating DAAs per month. If the uptake pattern of approximately 300 per month continues over the next year, this would imply that approximately 3,000–4,000 new DAA treatments might be expected to be initiated annually, assuming January 2012 through May 2012 indicate longer-term average usage in VA of DAAs. This uptake rate is then slightly higher than the 3,393 standard two-drug (PEG-RIB) treatments initiated in 2008, as the State of Care 2010 report states.41 It is however unclear if this uptake rate will continue in subsequent years (backlog vs. popularization vs. waiting for even newer drugs).

Figure 3 Uptake of DAA Therapies by VISN (x-axis denotes VISN number)

### Sub-question 1.2 How many unique people had an IL-28B test during 07/1/11–06/30/12? How did this differ across VISNs?

During the period of interest, 2,171 individuals had an IL-28B test. Currently VA IL-28B tests are send-outs. There was heterogeneity in use of IL-28B testing across VISNs. Only part of this variation is explained by differences in the number of treatment-eligible chronic HCV-infected Veterans in each VISN. Use of IL-28B testing across VISNs is represented in light shading in Figure 4, below.

Figure 4 Use of IL-28B Testing and DAAs by VISN

### Sub-question 1.3 Among people receiving DAA, how many had IL-28B testing? Among those with IL-28B testing, how many received DAA therapy? How does this differ across VISNs?

IL-28B testing is used for those not receiving DAAs, and DAAs are generally used without IL-28B genotyping. Only 306 patients used both, whereas 2,551 patients only used DAAs, and 1,865 patients only used IL-28B testing. VISNs differ on the rates of use of IL-28B testing in patients who received DAAs, with a national average just above 10 percent. VISN 22 had the greatest number of IL-28B tests, while VISNs 8, 16, and 21 had the greatest number of patients initiating DAA therapy. In some VISNs there were more patients initiating DAA therapy than getting IL-28B tests, while in other VISNs it was the reverse. Seven VISNs used testing in five percent or less of patients receiving DAA, whereas three VISNs used testing on 30 percent or more of these patients.

Using DAAs without information on a patient’s IL-28B genotype was common in many VA care settings, although there was diversity of practice. The reasons for these differences remain to be explored. They may include other uses of the IL-28B information, such as trying to understand why a patient failed to achieve sustained virologic response to a previous treatment. Tests may be more common in some settings because they are easier to order, because some subgroups of providers are more familiar with their use, or because they are more appropriate in some patient subgroups.

### Sub-question 1.4 Among persons who initiated DAA treatment during the study year, what is the length of their treatment episode?

The median length of boceprevir treatments was just under 28 weeks (see Figure 5). Of those who initiated boceprevir, 89% got to 8 weeks, 81% to 12 weeks, 76% to 16 weeks, and 29% to 32 weeks. Telaprevir episodes were much shorter per its therapeutic protocol. Median length of telaprevir treatments was between 12 and 16 weeks. None lasted beyond 28 weeks.

Figure 5 The Days on Treatment for Each DAA Appear Reasonably in Line with Its Therapeutic Protocols

The medication possession ratio indicated that most patients were highly adherent and that those who continued in treatment filled prescriptions promptly.

## KEY QUESTION #2 What will be the health impacts of using either of two available directly acting antivirals combined with pegylated interferon and ribavirin (triple therapy)?

With our model, we compared universal triple therapy to standard two-drug therapy over a five year analysis period for eligible GT1 HCV patients (N=48,000) (see Table 7). This comparison was made for three potential uptake rates: the current uptake rate (two percent per year), a doubled uptake rate (four percent per year), and a quadrupled uptake rate (eight percent per year). When compared to standard therapy, universal triple therapy was likely to reduce annual cases of decompensated cirrhosis by 10–29 (current uptake: 10; doubled uptake: 29; quadrupled uptake: 50). When comparing universal triple therapy to standard therapy, annual cases of hepatocellular carcinoma were likely to be reduced by 5–16 (current: 5; doubled: 16; quadrupled: 27). Finally, when comparing universal triple therapy to standard therapy, annual numbers of liver transplants are likely to be reduced by 0–1 (current: 0; doubled: 1; quadrupled: 2). Consequently, annual quality adjusted life years (QALYs) increased by 148–213 (current: 148; doubled: 213; quadrupled: 322).

Table 7 Annual Effect of Universal Triple Therapy on Health Outcomes over 5 Years

| Current Uptake Rate (2%/yr) | 2x Uptake Rate (4%/yr) | 4x Uptake Rate (8%/yr)
Cases of Decompensated Cirrhosis | −10 | −29 | −50
Cases of Hepatocellular Carcinoma | −5 | −16 | −27
Number of Liver Transplants | 0 | −1 | −2
Quality Adjusted Life Years | +148 | +213 | +322

N=48,000 eligible GT1 HCV

## KEY QUESTION #3 How will the magnitudes of the health impacts measured in Key Question #2 change if IL-28B patient genotyping is used to offer triple therapy to those less likely to benefit from two-drug pegylated interferon + ribavirin?

Using our model, we also compared IL-28B-guided therapy to standard two-drug therapy over a five year analysis period for eligible GT1 HCV patients (N=48,000) (see Table 8). This comparison was made for the same three potential uptake rates: the current uptake rate (two percent per year), a doubled uptake rate (four percent per year), and a quadrupled uptake rate (eight percent per year). In these comparisons, annual cases of decompensated cirrhosis are likely to be reduced by 8–26 (current uptake: 8; doubled uptake: 26; quadrupled uptake: 45), annual cases of hepatocellular carcinoma are likely to be reduced by 4–14 (current: 4; doubled: 14; quadrupled: 25), and annual numbers of liver transplants are likely to be reduced by 0–1 (current: 0; doubled: 1; quadrupled: 2). Consequently, annual QALYs increased by 110–145 (current: 110; doubled: 145; quadrupled: 225).

Table 8 Annual Effect of IL-28 Guided Triple Therapy on Health Outcomes over 5 Years

| Current Uptake Rate (2%/yr) | 2x Uptake Rate (4%/yr) | 4x Uptake Rate (8%/yr)
Cases of Decompensated Cirrhosis | −8 | −26 | −45
Cases of Hepatocellular Carcinoma | −4 | −14 | −25
Number of Liver Transplants | 0 | −1 | −2
Quality Adjusted Life Years | +110 | +145 | +225

N=48,000 eligible GT1 HCV

## KEY QUESTION #4 What will be the cost and resource use patterns when using either triple therapy or IL-28B-guided triple therapy?

Depending on uptake patterns, increased total expenditures for HCV treatment and care for individuals with GT1 HCV relative to standard two-drug therapy will likely be $32-$100 million annually. Table 9 below shows the details about these annual net expenditures vary depending on strategy and scenario.

Table 9 Average Annual Net Increase in Cost by Treatment Strategy and Uptake Rate over the 5 Years of the Analysis Relative to Standard Therapy

| Current Uptake Rate (2%/yr) | 2x Uptake Rate (4%/yr) | 4x Uptake Rate (8%/yr)
IL-28B-guided therapy | $32M | $76M | $115M
Universal triple therapy | $43M | $96M | $144M

N=48,000 eligible GT1 HCV

The table gives the additional cost of each treatment strategy compared to standard two-drug therapy. The costs include the direct cost of the new medications, the cost of treating side effects, as well as averted costs of advanced liver disease and lower care costs after achieving sustained virologic response. Importantly, average annual net costs, health outcomes and quality-of-life presented in these analyses should not be used for cost-effectiveness calculations as averted costs and downstream health benefits past year 5 are not counted in the 5-year projection of the effect on health care cost.