# REFERENCES

1 Liu S, Cipriano LE, Holodniy M, Owens DK, Goldhaber-Fiebert JD. New protease inhibitors for the treatment of chronic hepatitis C: a cost-effectiveness analysis. Annals of Internal Medicine. 2012;156(4):279-90. [pmid: 22351713].
2 Bini EJ, Bräu N, Currie S, et al. Prospective multicenter study of eligibility for antiviral therapy among 4,084 U.S. veterans with chronic hepatitis C virus infection. The American Journal of Gastroenterology. 2005;100(8):1772-9. [pmid: 16086714].
3 Butt AA, Khan UA, McGinnis KA, Skanderson M, Kent Kwoh C. Co-morbid medical and psychiatric illness and substance abuse in HCV-infected and uninfected veterans. Journal of Viral Hepatitis. 2007;14(12):890-6. [pmid: 18070293].
4 Butt AA, McGinnis KA, Skanderson M, Justice AC. Hepatitis C treatment completion rates in routine clinical care. Liver International. 2010;30(2):240-50. [pmid: 19889081].
5 Cheung RC. Epidemiology of hepatitis C virus infection in American veterans. The American Journal of Gastroenterology. 2000;95(3):740-7. Available at: http://www.ncbi.nlm.nih.gov/pubmed/10710068. [pmid: 10710068].
6 Cheung RC, Currie S, Shen H, et al. Can we predict the degree of fibrosis in chronic hepatitis C patients using routine blood tests in our daily practice?. Journal of Clinical Gastroenterology. 2008;42(7):827-34. [pmid: 18285716].
7 Cheung RC, Currie S, Shen H, et al. Chronic hepatitis C in Latinos: natural history, treatment eligibility, acceptance, and outcomes. The American Journal of Gastroenterology. 2005;100(10):2186-93. [pmid: 16181367].
8 Davila JA, Henderson L, Kramer JR, Kanwal F, Richardson PA. Utilization of Surveillance for Hepatocellular Carcinoma Among Hepatitis C Virus – Infected Veterans in the United States. Annals of Internal Medicine. Jan. 18. 2011;154(2):85-93. [pmid: 21242365].
9 El-Serag HB, Hampel H, Yeh C, Rabeneck L. Extrahepatic manifestations of hepatitis C among United States male veterans. Hepatology. 2002;36(6):1439-45. [pmid: 12447870].
10 Groom H, Dieperink E, Nelson DB, et al. Outcomes of a Hepatitis C screening program at a large urban VA medical center. Journal of Clinical Gastroenterology. 2008;42(1):97-106. [pmid: 18097298].
11 Hwang EW, Thomas I-C, Cheung R, Backus LI. Implications of rapid virological response in hepatitis C therapy in the US veteran population. Alimentary Pharmacology & Therapeutics. 2012;35(1):105-15. [pmid: 22060887].
12 Kamal A, Cheung R. Positive CAGE screen correlates with cirrhosis in veterans with chronic hepatitis C. Digestive Diseases and Sciences. 2007;52(10):2564-9. [pmid: 17415636].
13 Kayali Z, Tan S, Shinkunas L, et al. Risk factors for hepatitis C fibrosis: a prospective study of United States veterans compared with nonveterans. Journal of Viral Hepatitis. 2007;14(1):11-21. [pmid: 17212639].
14 Kramer JR, Kanwal F, Richardson P, et al. Importance of patient, provider, and facility predictors of hepatitis C virus treatment in veterans: a national study. The American Journal of Gastroenterology. 2011;106(3):483-91. [pmid: 21063393].
15 Kramer JR, Kanwal F, Richardson P, Mei M, El-Serag HB. Gaps in the achievement of effectiveness of HCV treatment in national VA practice. Journal of Hepatology. 2012;56(2):320-5. [pmid: 21756855].
16 Muir AJ, Provenzale D. A descriptive evaluation of eligibility for therapy among veterans with chronic hepatitis C virus infection. Journal of Clinical Gastroenterology. 2002;34(3):268-71. [pmid: 11873110].
17 Nguyen HA, Miller AI, Dieperink E, et al. Spectrum of disease in U.S. veteran patients with hepatitis C. The American Journal of Gastroenterology. 2002;97(7):1813-20. [pmid: 12135041].
18 Rowan PJ, Tabasi S, Abdul-Latif M, Kunik ME, El-Serag HB. Psychosocial factors are the most common contraindications for antiviral therapy at initial evaluation in veterans with chronic hepatitis C. Journal of Clinical Gastroenterology. 2004;38(6):530-4. [pmid: 15220690].
19 Smith JP, Dong MH, Kaunitz JD. Evaluation of a pharmacist-managed hepatitis C care clinic. AJHP. 2007;64(6):632-6. [pmid: 17353572].
20 Piasecki BA, Lewis JD, Reddy KR, et al. Influence of alcohol use, race, and viral coinfections on spontaneous HCV clearance in a US veteran population. Hepatology. 2004;40(4):892-9. [pmid: 15382122].
21 Groessl EJ, Weingart KR, Stepnowsky CJ, et al. The hepatitis C self-management programme: a randomized controlled trial. Journal of Viral Hepatitis. 2011;18(5):358-68. [pmid: 20529203].
22 Jakiche A, Paredez EC, Tannan PK, et al. Trend of depression and the use of psychiatric medications in U.S. Veterans with hepatitis C during interferon-based therapy. The American Journal of Gastroenterology. 2007;102(11):2426-33. [pmid: 17640322].
23 Butt AA, Wang X, Moore CG. Effect of hepatitis C virus and its treatment on survival. Hepatology. 2009;50(2):387-92. [pmid: 19591128].
24 Backus LI, Boothroyd DB, Phillips BR, Mole LA. Predictors of response of US veterans to treatment for the hepatitis C virus. Hepatology. 2007;46(1):37-47. [pmid: 17567830].
25 De Jesús J, Nieves-Santiago P, Rodríguez-Pérez F, Toro DH. Sustained virologic response among Latino veterans; does it represent the cure of chronic hepatitis C infection?. Puerto Rico Health Sciences Journal. 2010;29(4):397-401. [pmid: 21261181].
26 Getachew Y, Browning JD, Prebis M, Rogers T, Brown GR. Combination therapy for the treatment of hepatitis C in the veteran population: higher than expected rates of therapy discontinuation. Alimentary Pharmacology & Therapeutics. 2004;20(6):629-36. [pmid: 15352911].
27 Seal KH, Currie SL, Shen H, et al. Hepatitis C treatment candidacy and outcomes among 4318 US veterans with chronic hepatitis C virus infection: does a history of injection drug use matter?. Journal of Clinical Gastroenterology. 2007;41(2):199-205. [pmid: 17245220].
28 Anand BS, Currie S, Dieperink E, et al. Alcohol use and treatment of hepatitis C virus: results of a national multicenter study. Gastroenterology. 2006;130(6):1607-16. [pmid: 16697724].
29 Kanwal F, Hoang T, Kramer JR, et al. Increasing prevalence of HCC and cirrhosis in patients with chronic hepatitis C virus infection. Gastroenterology. 2011;140(4):1182-1188.e1. [pmid: 21184757].
30 Pyrsopoulos N, Jeffers L. Hepatitis C in African Americans. Journal of Clinical Gastroenterology. 2007;41(2):185-93. [pmid: 17245218].
31 Leykum LK, El-Serag HB, Cornell J, Papadopoulos KP. Screening for hepatocellular carcinoma among veterans with hepatitis C on disease stage, treatment received, and survival. Clinical Gastroenterology and Hepatology. 2007;5(4):508-12. [pmid: 17382601].
32 Ho SB, Groessl E, Dollarhide A, et al. Management of chronic hepatitis C in veterans: the potential of integrated care models. The American Journal of Gastroenterology. 2008;103(7):1810-23. [pmid: 18564122].
33 Beste LA, Ioannou GN, Larson MS, Chapko M, Dominitz JA. Predictors of early treatment discontinuation among patients with genotype 1 hepatitis C and implications for viral eradication. Clinical Gastroenterology and Hepatology. 2010;8(11):972-8. [pmid: 20692371].
34 Thompson AJ, Muir AJ, Sulkowski MS, et al. Interleukin-28B polymorphism improves viral kinetics and is the strongest pretreatment predictor of sustained virologic response in genotype 1 hepatitis C virus. Gastroenterology. 2010;139(1):120-9.e18. Available at: http://www.ncbi.nlm.nih.gov/pubmed/20399780. Accessed October 11, 2012. [pmid: 20399780].
35 Ho SB, Nguyen H, Tetrick LL, et al. Influence of psychiatric diagnoses on interferon-alpha treatment for chronic hepatitis C in a veteran population. The American Journal of Gastroenterology. 2001;96(1):157-64. [pmid: 11197246].
36 Dieperink E, Ho SB, Thuras P, Willenbring ML. A Prospective Study of Neuropsychiatric Symptoms Associated With Interferon-α-2b and Ribavirin Therapy for Patients With Chronic Hepatitis C. Psychosomatics. 2003;44(2):104-112. [pmid: 12618532].
37 Dieperink E, Ho SB, Tetrick L, et al. Suicidal ideation during interferon-alpha2b and ribavirin treatment of patients with chronic hepatitis C. General Hospital Psychiatry. 2004;26(3):237-40. [pmid: 15121353].
38 Rowan PJ, Al-Jurdi R, Tavakoli-Tabasi S, et al. Physical and psychosocial contributors to quality of life in veterans with hepatitis C not on antiviral therapy. Journal of Clinical Gastroenterology. 2005;39(8):731-6. [pmid: 16082286].
39 Silberbogen AK, Ulloa E, Mori DL, Brown K. A telehealth intervention for veterans on antiviral treatment for the hepatitis C virus. Psychological Services. 2012;9(2):163-73. [pmid: 22662730].
40 Silberbogen AK, Janke EA, Hebenstreit C. A closer look at pain and hepatitis C: Preliminary data from a veteran population. The Journal of Rehabilitation Research and Development. 2007;44(2):231. [pmid: 17551875].
41 Center for Quality Management in Public Health. The State of Care for Veterans with Chronic Hepatitis C. Palo Alto, California. U.S. Department of Veteran Affairs, Public Health Strategic Health Care Group, Center for Quality Management in Public Health. 2010.
42 Lai M, Afdhal NH. Clinical utility of Interlukin-28B testing in patients with genotype 1. Hepatology. 2012;56:367-372. [pmid: 22511388].
43 Thompson AJ, McHutchison JG. Will IL28B polymorphism remain relevant in the era of direct-acting anti-viral agents for hepatitis C virus. Hepatology. 2012;56:373-381. [pmid: 22511355].
44 Pearlman B, Ehleben C. Hepatitis C virus genotype 1 infection with low viral load and rapid virological response to peginterferon and ribavirin can be treated without a protease inhibitor, irrespective of IL-28B status or patient ethnicity. Hepatology. 2012;56(4, suppl):268A.