# METHODS

We undertook three main activities to answer these questions.

First, we performed an observational analysis of VA data to evaluate the uptake, use, and costs of therapies for HCV. This characterized the current state of DAA and IL-28B testing within VA in roughly the first year since adoption. Observational analysis was also used to estimate the cost of care for patients with liver disease.

Second, we adapted our previously-developed HCV computer model1 to more closely reflect VA patient populations with chronic GT1 HCV infections and patterns of HCV care in VA. In order to adapt this model, we performed a rapid literature review for chronic HCV-related studies from 2000–2012 that focused on VA populations. This review included peer-reviewed literature and for other reports. We performed preliminary analyses of VA administrative data to examine the usage patterns of DAAs and IL-28B in VA in the past year and the cost of care of patients with HCV. We used this information in the computer model so that it would reflect the VA patient population and care practices.

Third, using the adapted model, we then performed model-based projections of health outcomes and costs of alternative HCV treatment strategies.

## ADAPTING PREVIOUSLY DEVELOPED HCV MODEL TO VA

Brief description of the HCV computer model

The computer simulation model of HCV we use here has been described in detail previously.1 For convenience, we describe it here briefly. The model has two main parts:

1. [underlined: Decision model] that incorporates alternative treatment strategies for chronic GT1 HCV and potentially uses IL-28B genotyping to select the most appropriate treatment for a patient based on the IL-28B genotype results (Figure 1 Panel A).
2. [underlined: HCV natural history] model that projects the course of future health prior to initiating, during, and after treatment and also tracks clinical events, resource utilization, costs, morbidities, and mortality (Figure 1 Panel B).

Figure 1 Decision Model (Panel A) and HCV Natural History Model (Panel B)

The model is stratified by a set of cohort characteristics including age, sex, race, IL-28B genotype, and stage of liver fibrosis (Metavir score F0-F4). While IL-28B genotypes include CC, CT, and TT, the similarity of response to therapy for CT and TT and the relatively limited amount of data on these types, especially when further stratified by race, led us to combine them into non-CC.

Three main strategies are included in the model. The first is standard therapy, the continued use of 48 weeks of Pegylated Interferon + Ribavirin for all patients regardless of IL-28B genotype (i.e., without genotyping them). The second strategy is universal triple therapy, the use of DAAs in combination triple therapy for all patients regardless of IL-28B genotype (i.e., without genotyping them). The third strategy considered is IL-28B guided triple therapy. In the strategy, patients are first tested for the IL-28B genotype. Patients with CC type are most likely to respond to standard therapy and are directed to the treatment. Those with non-CC types are provided with triple therapy. All strategies use specific response guided protocols (not shown). Models for all strategies include risks, costs, and quality-of-life reductions due to side-effects as well as the possibility of non-adherence and discontinuation above and beyond response guided protocols.

The HCV natural history model tracks individuals at 4 week intervals. During each interval, people have the chance of transition along the solid black arrows which represent progression through various states of liver fibrosis, advanced liver disease including decompensated cirrhosis, hepatocellular carcinoma, and liver transplantation. At all times, people have an age, sex, and race specific risk of death with elevated risks for advanced liver disease. Successful treatment that leads to SVR and cure allows individuals to transition along the dashed arrows to “recovered” states that are stratified by fibrosis severity. In recovered states, individuals have lower mortality risks and lower ongoing medical care costs than in the corresponding states prior to recovery.

The model considers chronic GT1 HCV individuals who are HCV treatment naïve who do not have a co-occurring HIV infection.

### Literature Review of Veteran-related Chronic HCV-related Studies from 2000–2012

We conducted a rapid evaluation of references for information on chronic HCV infection in U.S. Veterans. Because of the limited time available, we did not undertake the formal methods of a systematic literature review. We searched PubMed for published studies from 2000–2012 on topics that included both “chronic HCV” and “veterans.” Identified abstracts were reviewed and full text of articles obtained. We further reviewed these articles’ bibliographies for other important sources that the search may have missed. Additionally, we performed web searches and VA-specific website searches to locate VA reports and other public, non-journal-published data relevant to these topics. We then extracted information from these sources. When we combined information from the studies and sources described above, we gave precedence to recent studies, large studies, representative studies, and high-quality studies. We did not assess articles formally for quality and attempted to be as inclusive as possible. Articles were excluded that did not report provide sufficient detail on a needed parameter.

Mortality in Veterans regardless of HCV has been modeled actuarially as reflected in the VA’s VetPop 2007 model (www.va.gov/VETDATA/Demographics/Demographics.asp).

Additional information on mortality relating to HCV and liver disease is reported in a number of studies.23,29,31 We combined this information on VA-specific age and sex-stratified mortality rates, using NHANES (National Health and Nutrition Examination Survey) III linked estimates of hazard rate ratios for mortality due to HCV by race/ethnicity to reflect the background mortality patterns of individuals within VA with chronic HCV infections.

### Preparing the Model for Performing Preliminary Projections on Cost and Outcomes for the VA’s Chronic HCV GT1 Population

The preliminary resource analysis considered a representative cohort of chronic HCV GT1 infected individuals in VA. In the analysis, scenarios are considered that use DAAs (Key Question 2, Key Question 4) alone or with IL-28B patient genotyping (Key Question 3, Key Question 4) as an alternative to standard two drug therapy and in which treatment uptake may differ from the past. Each scenario examines the costs of delivering such treatments over a 5 year window of time as well as the health benefits within this 5 year window.

Importantly, costs and benefits are reported for these 5 particular years only. As they do not include subsequent costs or benefits beyond these 5 years, this analysis CANNOT be used to assess the cost-effectiveness of these treatment strategies. Cost-effectiveness analysis employs a lifetime time horizon, considering all costs and benefits over the patients’ lifetimes.

### Representative Cohort of Chronic HCV GT1 Infected Individuals in VA

We defined a representative cohort of chronic HCV GT1 infected individuals in VA based on published studies of VA HCV populations and other VA-specific documents and data that are described in the results.

### Treatment-eligible Patient Population and Uptake Scenarios

To provide estimates of total costs due to DAAs and IL-28B genotyping, it is necessary to determine the size of the treatment-eligible patient population and likely patterns of treatment uptake. We then combined the update scenarios with the treatment-eligible population for analyses.

## PRELIMINARY ANALYSES OF VA ADMINISTRATIVE DATA

The VA Health Economics Resource Center examined national data extracts from the VA Decision Support System (DSS) to identify use of DAA medications and IL-28B testing VA for the period of July 2011 through June 2012. Administrative data were also used to identify the size of the population with HCV infection. VA cost data from the 2010 federal fiscal year were analyzed to determine the cost of care for patients with different stages of liver disease.

### VA Population with Chronic HCV Receiving VHA Care

The VA hospital discharge and outpatient visit files for the year ending 9/30/2011 were used to identify all persons who received at least one service that was assigned an ICD-9 diagnosis code for HCV. For this time period, the national prevalence of an HCV ICD-9 diagnosis code is approximately 2.6%.

### Prescription Data on DAA Medication Use

The VA DSS National Data Extract of prescription data was analyzed for the use of DAA medications boceprevir or telaprevir. A record was considered to refer to a DAA if all of the following were true:

- National Drug Code (NDC) was for one of these DAA medications
- Internal entry number (IEN) from the VA drug file was for one of the DAA medications
- The DSS Intermediate Product (IPNUMBER) was either for a specific DAA or for a “new drug.”

The text in the drug description field was not used to identify DAA medications. The text “telaprevir” did not appear in any record. The text “boceprevir” did not appear in the drug description field of these records until the 2012 fiscal year. An additional 169 records that had text description that included the string “boceprevir FY12”, and DSS intermediate product number for pegylated interferon, were reviewed. Records that had a quantity of medication that was consistent with boceprevir were included in the analysis.

### Data on IL-2B Genotype Testing Use

The DSS National Data Extract of laboratory orders was evaluated. All records with a laboratory test description containing the text “IL-28” were included in the analysis.

### VISN-level Analyses

To enable VISN-level analyses, we assigned VISN number using the VISN recorded in the first record for a DAA prescription fill in the pharmacy data, or the first IL-28B test in the laboratory data. We used the first record in order to be consistent in characterizing number of new treatments and the length of treatment episodes. When we combined the lab data (on IL-28B testing) with prescription data (on DAA fills), if the VISN was not the same in the two sources, the conflict was resolved by using the VISN in the earlier record.

### Key Question #1 Analysis Plan: What are the current usage patterns of directly acting antivirals and of IL-28B patient genotyping in the VA health system? And how do these patterns differ by VISN?

We divided this overarching question into a number of related sub-questions answered individually below.

#### Sub-question 1.1 How many people initiated DAAs during 07/1/11-06/30/12? How did this differ across VISNs? How has this changed since the introduction of DAAs into VA?

We created a person-level file using prescription records during the year 7/1/11-6/30/12. We summarized the data so that there was one record per patient. The summary record included a patient identifier, a variable to indicate if the patient initiated boceprevir, and the month when this medication was first dispensed. Each summary record also included a variable to indicate whether telaprevir was initiated and the month that this medication was first dispensed. This patient-level file was used to determine the number of unique persons initiating DAA, and the number initiating each medication.

#### Sub-question 1.2 How many unique people had an IL-28B test during 07/1/11-06/30/12? How did this differ across VISNs?

We created a person-level file from qualifying IL-28B laboratory records from the study year. The file included the patient identifier and an indicator that the patient received at least one IL-28B test during the study year. We report the total number of patients who had an IL-28B test.

#### Sub-question 1.3 Among people receiving DAA, how many had IL-28B testing? Among those with IL-28B testing, how many received DAA therapy? How does this differ across VISNs?

We approached this question in two ways. We first compared the counts of individuals initiating DAA therapy and being tested with IL-28B testing by VISN without examining whether the counts were of the same individuals or not. Second, we combined the person-level prescription and laboratory files from the study year, and created a 2 x 2 table to show the number receiving a DAA medication, an IL-28B test, or both. Note that the cell for neither is not included, as persons had to receive either a DAA medication or an IL-28B test to be included.

#### Sub-question 1.4 Among persons who initiated DAA treatment during the study year, what is the length of their treatment episode?

We examined how long individuals initiating DAAs were on treatment before ending it. From the data available, we could not ascertain the reason for ending treatment (e.g., treatment success, discontinuation because of an adverse event, etc.). Our analysis considered the incomplete nature of the data available. We extracted data from 7/1/2011 until 5/31/2012. In this analysis, we excluded data from June, 2012, to be certain that results would not be affected by possible incomplete processing of prescriptions filled at the end of the study period. We had between one month and one year of prescription data on those who initiated DAA treatment in this period.

We evaluated treatment duration using a method similar to a survival analysis. We used these data to characterize the percentage of persons with available data who were still in treatment at each interval of time. We created one record for each patient for each medication, and called this a treatment episode. We found the length of treatment and the length of follow-up. We ignored any treatment gaps resulting from delays in filling prescriptions in defining the duration of treatment. We use the following procedure:

First, we excluded cases with uncertain data. Most records reported the days’ supply of medication that was dispensed. If this field was missing, we estimated the days of supply by dividing the quantity of drug by the recommended daily dose (12 pills for boceprevir or 6 pills for telaprevir). We excluded 3% of the records with a value of more than 90 days of supply dispensed at single prescription fill date.

Second, we then created an episode data base with one record for combination of person and drug (a small number of persons initiated treatment with both drugs, and when this occurred we included both starts in our data). Although data were extracted for the month of June, 2012, we excluded these data as we were uncertain if all records from that month had been processed. We created an episode database with the following variables:

- [underlined: Medication]: The medication for this episode, either boceprevir or telaprevir.
- [underlined: Total days supply]: The total day supply in all prescription fills.
- [underlined: Days of treatment]: The number of days of treatment was defined as the greater of two numbers: the total number of days’ supply of medication that was dispensed, or the number of days between the date the prescription was first dispensed and the date that the last prescription would have been exhausted. The first number, days’ supply of medication, represents the length of treatment in patients who were prompt in filling prescriptions. The second number represents the duration of treatment in patients who were not prompt in refilling prescriptions, and includes some days in which medication doses were missed.
- [underlined: Medication possession ratio]: The medication possession ratio was the total days of supply divided by the number of days from treatment initiation to exhaustion of last prescription. This number was less than 100% in patients who did not fill prescriptions on time. This number was more than 100% when prescriptions were refilled promptly. In this case, there was an accumulated a supply of medication available to take when this last fill would otherwise have been exhausted.
- [underlined: Days of follow-up]: The days of follow-up was the number of days from treatment initiation to the end of follow-up (5/31/12), that is, the date that information about this treatment episode was censored by limits of the data extract. Episodes in which days of supply exceeded the days of follow-up are censored; there is insufficient information to know the length of that treatment episode. There is sufficient information to know that the treatment lasted at least as long as the number of days of follow-up.
- [underlined: Month in which treatment was initiated]: The month in which the first prescription We used this information to see if there was a trend in the number of was filled. individuals starting treatment.

Third, we characterized length of treatment, considering the limitation of follow-up. We considered the percentage of people who were still receiving the DAA in each 4 week interval (after 4 weeks, after 8 weeks, after 12 weeks, etc.). For each interval, we computed: 1) the denominator (number who could have been treated this long, that is, whose follow-up was not yet censored); and 2) the numerator (number actually treated this long). For example, we evaluated the episode database for boceprevir to see treatments that lasted at least 4 weeks. We counted as the denominator the number of persons still being followed, those who initiated treatment more than 28 days before the last date in the prescription data. We counted in the numerator the number of these persons (with 28 days of follow-up) who had at least 28 days of treatment. Note that it was possible for an individual to have more days of medication than days of follow-up, and that we only included in the numerator those eligible for the denominator. This analysis was repeated for subsequent 4 weeks intervals, until there were no more cases that met the criteria for the denominator (52 weeks).

### Key Question #2 What will be the health impacts of using either of two available directly acting antivirals combined with pegylated interferon and ribavirin (triple therapy)?

The analytic plan for addressing Key Question #2 involved three steps:

1. [underlined: Synthesizing VA-specific data into model-usable inputs]: Information from administrative data analyses and literature reviews were combined to produce inputs usable by the model.
2. [underlined: Running VA-specific cohorts through the simulation model under each treatment strategy at various rates of uptake for the new DAAs]: Simulations were conducted using computers and Tree Age modeling software. Under each combination of treatment and uptake rate, the model produced a set of outputs that were then analyzed to address the Key Question.
3. [underlined: Computing multiple, annual health impacts over a 5 year horizon]: Improving treatment efficacy has the potential to ameliorate a variety of non-fatal and fatal outcomes. Non-fatal outcomes included decompensated cirrhosis, hepatocellular carcinoma, and the need for liver transplant. We considered mortality due to chronic HCV in general and to advanced liver disease in particular. We combined the effects of non-fatal and fatal outcomes into a single, standard measure – quality-adjusted life years (QALYs). All outcomes were computed over a 5 year horizon and reflect the annualized difference between standard two-drug therapy and alternatives that included a DAA as part of HCV treatment. As the goal was to consider short-term effects within the VA Health System, results DO NOT consider lost life years or reduced quality-of-life for individuals in years after the 5 year horizon and therefore likely underestimate the full health benefits of patients’ lifetimes.

### Key Question #3 How will the magnitudes of the health impacts measured in Key Question #2 change if IL-28B patient genotyping is used to offer triple therapy to those less likely to benefit from two-drug pegylated interferon + ribavirin?

The analytic plan for Key Question #3 was the same as that of Key Question #2 except that instead of evaluating universal triple therapy, the treatment strategy that was evaluated was IL-28B patient genotyping to guide who receives standard two-drug therapy and who receives triple therapy with a DAA.

### Key Question #4 What will be the cost and resource use patterns when using either triple therapy or IL-28B-guided triple therapy?

The analytic plan for Key Question #4 was the same as that of Key Questions #2 and #3 except that the cost impacts over a 5 year horizon were considered. This meant that costs of treatment, contingent on response guided therapy protocols and adherence, were tallied for individuals initiating treatment. Costs depended on treatment effectiveness, as the model tallied the effect of sustained viral response in averted treatment of advanced liver disease. Like health benefits, costs were only considered for a 5 year period. The effectiveness of treatment strategies after the 5 year horizon were not considered, and therefore the estimates are likely underestimate the full lifetime cost effects and do not represent lifetime horizon needed to estimate cost-effectiveness.

The costs of inpatient and outpatient care are based on relative values of the national average Medicare reimbursement rate, adjusted to correspond to actual VA expenditures (the HERC average cost estimates). These estimates were based on an analysis of cost of care provided to VA patients with HCV who received care in the 2010 federal fiscal year conducted by the Health Economics Resource Center. Pharmacy costs were based on data in the DSS prescription-level national data extract from the same period, with the exception of cost of DAA medications. All cost estimates include both the direct costs of care and the indirect (overhead) costs of providing that care.

## PEER REVIEW

A draft version of this report was reviewed by six technical experts as well as clinical leadership. Their comments and our responses are presented in Appendix A.