# RESULTS

We reviewed 807 titles and abstracts from the electronic search, and identified an additional 94 from reviewing reference lists and performing manual searches for recently published and unpublished or ongoing studies (Appendix C, Figure 1). Eighty-one systematic reviews met our inclusion criteria and, of these, we selected 17 that were the most recent and broadly scoped.

We selected a representative review for 7 patient populations and 10 intervention types. The effects of transitional care interventions on hospital readmissions and mortality are summarized in Tables 1 and 2 (Appendix A). The effects of interventions on other clinical and utilization outcomes are summarized in Tables 3 and 4 (Appendix A), along with any information from the reviews relevant to implementation considerations (setting or intervention characteristics). All reviews used reproducible systematic searches, specified inclusion and exclusion criteria, and assessed the quality of included studies (most using established criteria – see Tables 1 and 2). Almost none of the reviews, however, rated the strength of the overall body of evidence.

## WHAT TRANSITIONAL CARE INTERVENTION CHARACTERISTICS ARE ASSOCIATED WITH REDUCTIONS IN READMISSION RATES?

Overall, it is very difficult to identify specific intervention characteristics that are necessary for successful care transitions. There is some consistency among different patient populations and different settings that successful interventions are more comprehensive, touch on more aspects of the care transition, extend beyond the hospital stay, and are flexible enough to respond to individual patient needs. However, the strength of evidence supporting these overarching conclusions should be considered low because these are indirect, post-hoc comparisons across literature that includes many different intervention types, studied in varied populations and clinical settings, and implemented in different ways. We found very little comparative effectiveness data.

### Transitions of care taxonomies

Two reviews developed detailed taxonomies to guide their analysis of the literature.15,18 One review examined transitional care interventions in patients with stroke or MI, and explicitly set out to define the key characteristics of interventions and to determine whether outcome effects were modified by intervention, patient, or system characteristics.15 Their taxonomy specifies a number of intervention characteristics including: 1) transition type (hospital to home, nursing facility to home), 2) intervention target (patient, caregiver, or provider), 3) key processes (education, counseling, etc), 4) key personnel involved, 5) method of contact, 6) intensity and complexity, and 7) outcomes targeted.

Despite the development of a detailed taxonomy and a large number of fair- and good-quality trials, the authors were unable to draw firm conclusions about which intervention characteristics are associated with benefit, and how population and health system setting characteristics might modify effects. They cited inconsistency in intervention and usual care definitions, lack of statistical power, variation in study endpoints, methodologic shortcomings of some studies, and limited generalizability (most studies were single-site and non-US) as key limitations to the body of evidence.

A more recent review developed a similar type of taxonomy. The authors also systematically characterized intervention intensity by creating a “comprehensive support” variable which was based on number of patient interactions, number of personnel involved, number of intervention components, and the ability of the intervention to address self-management needs. A meta-regression including 42 trials, the vast majority of which included general medical patients or patients with CHF and were considered to be methodologically sound, found interventions were overall associated with reductions in readmissions (pooled RR 0.82, 95%CI 0.73-0.91). They found the observed benefits were mostly contributed by interventions with the most comprehensive support (RR readmission in the 7 studies with highest comprehensive support scores compared to 15 studies with the lowest scores, 0.63, 95% CI 0.43-0.91). They also found that the observed benefit was mainly limited to studies published before 2002 (RR readmission of studies published in 2002 or after, 1.47, 95% CI 1.10-1.96). They speculate that, over the last decade, usual care has improved, making it more difficult to demonstrate the incremental benefit of transitional care interventions.

### The effects of different intervention types

An Agency for Healthcare Research and Quality (AHRQ) review in patients with CHF categorized interventions into one of 6 types: home-visiting programs, structured telephone support, telemonitoring, outpatient clinic-based (which included multidisciplinary CHF clinics, primarily educational, and other).19 This review found interventions with multidisciplinary HF clinic visits or home visits reduced both all-cause readmissions and mortality, with NNTs below 10 for readmission and 18-33 for mortality (for MDS-HF clinic and home visiting programs, respectively). Structured telephone support interventions produced a similar mortality benefit but did not reduce all-cause readmissions. The authors of this CHF review found that, across intervention types, the key processes of care that seemed to be associated with reduced readmissions included: self-management education delivered in person, early post-discharge contact, a point of post-discharge contact, and the ability to individually tailor the intervention.

One review of patients with stroke or myocardial infarction described 5 intervention types: 1) hospital-based discharge preparation, 2) hospital-based patient and family education, 3) community-based patient and family education, 4) community-based models of support interventions, and 5) chronic disease management models of care.20 They found moderate-strength evidence that early supported discharge of stroke patients (short hospital stay followed by intensive home care with a multidisciplinary team) shortened length of stay without adversely impacting readmissions or mortality. Specialty care after an MI was associated with reduced mortality, but the strength of evidence was low (largely from one VA observational study).

Tables 2 and 4 summarize reviews focused on specific intervention types (Appendix A). Several show promise in reducing readmissions and/or mortality.21-23 Many of the more successful interventions, in reality, touched on numerous aspects of the care transition and took place across settings. For example, according to a Cochrane review updated in 2013, there is moderate-strength evidence that structured and individually tailored discharge planning reduces readmissions within 90 days, and hospital length of stay.21 However, the discharge planning interventions were likely complex and included numerous care processes, with substantial variation among studies in the exact combination of care processes used. In 9 of the interventions, a nurse “advocate” helped with discharge planning activities and care coordination. Twelve of the interventions included post-discharge follow-up.

By contrast, a review of COPD patients found 5 trials of interventions that began after hospital discharge and did not include many care processes – such as provider continuity, ensuring post-discharge follow-up, and patient-centered discharge education – that have been part of interventions that were successful in other populations. The interventions did not consistently reduce readmissions or mortality.24

Kwan et al examined peri-discharge medication reconciliation interventions.23 They found one intervention that reduced clinically significant adverse drug events (ADE) and post-discharge utilization, but this intervention included additional care processes such as post-discharge follow-up.25 They otherwise found that interventions focused largely on medication reconciliation found many clinically significant unintended discrepancies (median proportion of patients with at least one discrepancy, 45%), but little evidence that these focused interventions impacted utilization or reduced ADE.

### Home visits

It is unclear whether home visits are a necessary component of transitional care interventions. A meta-analysis of trials including general medicine or CHF patients did not find that the setting of care delivery influenced outcomes; however, all but one of the most comprehensive interventions included home visits in their model.18 On the other hand, the CHF review discussed above found evidence in support of interventions that did and did not include a home visit component.19 They found insufficient evidence directly comparing interventions with and without home visits.

Hospital-at-home interventions were associated with reductions in readmissions and mortality across 61 trials, among which medical populations were best studied.22 Specific components of the included interventions were not well-described, and periods of observation for outcomes were not specified. Interventions were associated with greater patient and caregiver satisfaction in the vast majority of studies reporting such outcomes. The interventions examined in this review were largely designed to substitute home care for part or all of a hospitalization, though the degree of “admission substitution” did not appear to be associated with differences in effects. Of note, similar to the Leppin review, they found that much of the observed benefit was found in studies published before 2003.^22^

### Telephone-based and telemonitoring interventions

One review focused on post-discharge remote monitoring, mostly with telephone, in patients with CHF.26,27 Similar to the 2014 AHRQ CHF review referenced above, there were 2 types of telephone interventions described: structured telephone support and telemonitoring. Structured telephone support (STS) interventions typically included periodic scripted telephone calls from nurses to review symptoms, interval physiologic data such as weight, and self-management skills. Telemonitoring interventions, on the other hand, focused on remote monitoring of physiologic data and, typically, further phone contact was only triggered by abnormal vital signs or weights. STS interventions reduced long-term (≥ 6 month), but not short-term (2-3 month) heart failure readmissions, and were associated with reduced long-term mortality.19,27 Though one review noted a trend towards reduced mortality with telemonitoring interventions, both reviews noted the substantial methodologic shortcomings of this literature and the inconsistency of results across studies. The AHRQ review found insufficient evidence (one methodologically flawed trial) of the comparative effectiveness of STS and telemonitoring interventions.

Two reviews examined the effects of post-discharge follow-up calls. An older Cochrane review from 2006 focused on calls performed by hospital-based personnel.28 Though 33 studies including 5,110 patients were included in this review, there was inconclusive evidence of the effectiveness of these interventions, largely because of the low methodologic quality of most included studies. A more recent review included 3 studies of calls delivered by primary care personnel.29 The authors of this review similarly concluded there was insufficient evidence of the effects of post discharge calls on utilization, though they did find that the interventions were associated with higher rates of primary care engagement.

## DO THE EFFECTS OF TRANSITIONAL CARE INTERVENTIONS VARY DEPENDING ON THE SETTING IN WHICH THEY ARE IMPLEMENTED?

Theoretically, the design of an intervention and its effects might depend on factors such as the presence of a shared electronic medical record, access to community resources, integration of primary and hospital care, and the presence of a medical home. However, we found no evidence directly examining whether intervention effectiveness depends on the health system context within which they are implemented. Moreover, the transitional care literature generally has provided only scant descriptions of the health system context of the interventions.

### VA studies

From the reviews included in our report, we identified 9 studies conducted in VA settings summarized in Table 5 (Appendix A). Overall, there is no clear pattern of effect differences between studies conducted in VA and non-VA settings, but there are relatively few studies. Of note, 2 studies examining the effects of increasing primary care access were conducted in VA settings – both actually found an increased risk of readmissions.30,31

### Transitions of care and the patient-centered medical home

A recent review for AHRQ included 31 studies of PCMH interventions, most of which included care coordination activities – most commonly, hospital-to-home transitional care coordination.32 The authors found moderate-strength evidence that PCMH interventions were associated with higher patient-reported levels of care coordination. They found low-strength evidence that PCMH interventions lowered emergency room use, though it is unclear which components of the PCMH mediated this effect. On the other hand, they found low-strength evidence that PCMH had no effect on hospital admissions (readmissions were not reported separately).

## HOW DOES THE CHOICE OF PATIENT POPULATION TARGETED INFLUENCE THE EFFECTS OF TRANSITIONAL CARE INTERVENTIONS?

The relative importance of careful patient selection, as compared to intervening on an unselected group of patients, is unclear. Many studies in these reviews used inclusion criteria which selected patients who were at high risk for readmission because of older age, significant medical comorbidity, and/or a history of high utilization. However, few reviews explicitly examined variation of intervention effects based on patient criteria. One review found studies that did and did not use high-risk patient selection criteria had similar results.23 A meta-regression of trials including general medical or CHF populations did not find significantly different effects between studies without age restrictions and those which included only patients over 65 years of age (interaction p = 0.24).18 Similarly, a review of hospital-at-home studies did not find a clear difference in effects among studies in patients younger than 70, 70-73, and older than 74 years.22

While many studies identified high-risk populations based on simple inclusion criteria, almost no studies explicitly used multivariable readmission risk prediction tools to identify high-risk patients for inclusion. We found one review with one trial comparing the effects of risk-prioritized post-discharge telephone calls to unprioritized calls.33 Groups were randomized and matched on key demographic and comorbidity characteristics. The call structure and health care team were the same in both groups, but calls in the intervention group were delivered first to the sickest patients as defined by an electronic utilization prediction tool. Calls in the intervention group were delivered sooner. There were significantly fewer readmissions in the intervention group over 30 days.

Some of the reviews also speculated that focusing on specific groups of patients allowed disease-specific customization of interventions and supported expertise development. For example, one review found that interventions in acute myocardial infarction patients which focused on effective use of disease-specific medications were associated with a mortality benefit, though this was largely driven by one study.34 Another review examining comprehensive geriatric assessment interventions found that gains in the combined outcome of mortality and functional decline were only associated with interventions delivered in a geriatric ward setting.35 The authors speculate that the multidisciplinary team of providers developed more expertise and facility with the patient population.

We found inconsistent results among reviews examining interventions focused on specific populations. There were several types of interventions that improved readmissions and/or mortality in CHF patients.19 Multidisciplinary post-discharge heart failure clinics were associated with reduction in readmissions, while primary care based follow-up interventions did not improve outcomes. In one review of studies in COPD patients there was no consistent evidence of benefit, and one of the interventions was associated with increased mortality. However, the vast majority of intervention components in these studies took place after hospital discharge so it is unclear if the differences in results between CHF and COPD populations relate to patient population or the interventions themselves. There was not enough good-quality literature in mental health or surgical populations to draw firm conclusions.