# METHODS

We conducted a review of published systematic reviews. “Transitional care” is a loose, broadly defined term that can be applied to many different types of interventions and has been studied in many different patient populations. We use the term “intervention type” to refer to single- or multicomponent interventions that used a similar approach or bundle of care processes (eg, telemonitoring, hospital-at-home), or addressed a similar aspect or key process of the care transition (eg, medication reconciliation). Patient populations are defined according to clinical condition (eg, CHF) or demographic characteristics (eg, geriatric). There are numerous characteristics that further distinguish interventions from one another. “Intervention characteristics” refer to any of the following (derived from an existing taxonomy)15: transition type (hospital to home, hospital to nursing facility), intervention target (patient, caregiver), key processes (education, personal health record), key personnel involved (nurse, social worker), method of contact (phone, home visits), and intensity and complexity.

From an initial review of the literature, we recognized that most systematic reviews typically either examined different transitional care intervention types in a given patient population, or examined a given intervention type in a variety of patient populations. We identified categories of patient populations and intervention types to help guide our literature search, study selection, and synthesis (Appendix A, Tables 1 and 2). The intervention type and patient population categories were developed iteratively with input from a panel of content experts, a “horizon scan” of the literature, and with input from our study team. The search strategy is presented in Appendix B.

We focused on reviews that reported hospital readmissions as an outcome, regardless of whether it was the primary outcome. However, we summarized other outcomes reported by each review.

Within each patient population or intervention type of interest, we first identified reviews that fulfilled key quality criteria: 1) clearly reported their search strategy, 2) reported inclusion and exclusion criteria, and 3) conducted an appraisal of the internal validity of the included trials.16,17 If there was more than one review within each category fulfilling these criteria, we prioritized the most recent review and, if there were several recent reviews meeting quality criteria, we prioritized those with the broadest scope. We discussed the ultimate choice of review as a group and resolved any disagreements through consensus.

Because of its relevance to the current VA practice environment, we also reviewed medical home literature to examine the effects of transitional care activities within the context of the medical home (see search strategy, Appendix B).

From each review we abstracted search dates, inclusion criteria, patient population characteristics, readmission and mortality outcomes, other clinical and utilization outcomes, and any data that would inform intervention implementation (ie, characteristics of the setting or the intervention that modified the effect of the intervention). We also developed brief narrative summaries of findings for each patient population or intervention type. These narratives were compiled into a single document and reviewed independently by each of the authors of this report, who then compiled a brief list of key themes in the evidence as well as recommendations for stakeholders based on their interpretation of the narratives.

Policy implications were informed by interpretation of the evidence in the context of clinical and research experience of different members of the study team, which includes: experience with implementation and evaluation of transitional care interventions (DLK, HE), readmissions policy research (DLK, SJ, HE, DK), medical home implementation and evaluation in VA (DLK), administrative leadership (DK, HE), inpatient clinical practice in VA (DLK, DK, JC, KR) and non-VA settings (HE), outpatient clinical practice in VA (DLK) and non-VA settings (HE), and policy development at federal and state levels (SJ).