# DISCUSSION

## SUMMARY OF FINDINGS

We examined 17 systematic reviews across different patient populations and representing a variety of intervention types in order to provide a broad overview of the care transitions literature. While there have been numerous examples of interventions that have been successful in reducing readmission rates, there were no patient population or intervention categories within which transitional care interventions were uniformly successful.

It is not surprising that there are many sources of heterogeneity in a field as broadly defined as transitional care. Variations in population studied, intervention definition, personnel, outcome definition, and setting make it difficult to identify definitive recommendations in support of a specific intervention type that should be broadly implemented. Nevertheless, there are several important generalizations we drew from the literature.

1. Interventions that address more components of the care transition are probably better than those that address fewer.
2. Successful interventions tended to include the means to assess and respond to individual peri-discharge needs.
3. There is very little data supporting the effectiveness of interventions isolated to either the pre- or post-discharge settings. Successful interventions which were largely implemented in one setting still often included components (such as home visits, a single point of contact, and/or telephone calls) that bridged settings. On the other hand, in select populations – such as patients with CHF – there is some evidence supporting post-discharge interventions such as structured telephone support and multidisciplinary CHF clinics.
4. It is not clear to what extent and for whom post-discharge home visits are a necessary component of care transitions.
5. The vast majority of the care transitions literature has been hospital-focused, with very little literature examining the role of primary care teams during the transitions of care. There is a growing literature examining the effects of medical home interventions, most of which include cross-site care coordination activities; however, the characteristics of successful care transitions within the medical home context have not been well explored.
6. Many interventions that have demonstrated a reduction in readmission rates have included patients at high risk for rehospitalization because of underlying comorbidities such as CHF and/or because of additional factors such as prior utilization.
7. Interventions designed to address the needs of patients with complex, chronic medical illness have been the best studied. It is unclear whether the success of some interventions studied in these patient populations reflects the content expertise intervention personnel might develop in working with specific patient populations, the higher baseline risk of poor outcomes among these patients, or sensitivity of chronic medical illness to transitional care improvements. However, there are many notable exceptions even among patients with chronic medical illness – for example, we found little evidence of benefit in COPD populations, though many transitional care components were missing from these studies. There is little good-quality transitional care literature in mental health or surgical populations.
8. Reviews that assessed the association between timing of publication and outcome effects, suggest that many of the interventions demonstrating benefit were conducted more than a decade ago.
9. In order to allow for better collation of results from trials, development of a standard taxonomy is needed. This taxonomy should include both population descriptors as well as intervention descriptors.

## POLICY IMPLICATIONS

### Understand the spectrum of care transitions activities and diagnose systems gaps

There are many potential steps in the care transition that, if not sufficiently addressed, could degrade the quality of the care transition. Focusing on just one of these steps – like medication reconciliation – alone is unlikely to yield big changes for a population of patients. The pathways to readmission are likely many, as suggested both by the inability to accurately anticipate which patients will be readmitted,36 and by case review studies characterizing underlying factors contributing to preventable readmissions.30 As discussed above, one of the recurring themes in the literature is that interventions which account for more aspects of the care transition and bridge in- and outpatient sites of care tend to be more successful.

The problems with recommending that a specific intervention be broadly implemented across VA sites include both the lack of evidence supporting such a recommendation and the likelihood that the transitional care gaps are not the same in all VAs, nor for all populations of patients treated at VAs. Moreover, we found at least 2 large reviews which showed that more recently published studies were less likely to have shown an improvement in outcomes, suggesting a need to think critically about broadly implementing resource-intensive interventions in the current health system context.18,22

Rather, we propose institutions use a standardized process for assessing the current state of transitional care. As part of this review, we developed a transitional care map (Appendix C, Figure 2), which diagrams the basic steps that should be considered when targeting areas for improvement. The elements on this map were identified through several means: 1) activities that have consistently been part of successful transitional care interventions, 2) elements that have been part of prior consensus statements, and 3) consensus among our own research team. Ideally, the map should be part of collaborative discussions between hospital and outpatient administrators and clinicians.

It is important to adapt the map to different patient populations. For instance, existing transitional care processes and gaps are likely to be quite different for patients who are established in a VA PACT team and those who do not regularly receive primary care at a VA. It is likely not feasible for each institution to examine its transitional care processes for all patient populations served. Rather, institutions may choose to focus on particular patient populations experiencing poor outcomes (such as high readmission rates), or for whom providers perceive substantial gaps in transitional care.

The map is a menu of many elements that have been part of successful interventions and some (such as outpatient to inpatient communication at the transition into the hospital) that have not been adequately studied but in the group's opinion represent an important opportunity for quality improvement investigation. The map has not been tested empirically and its steps are not necessarily meant to apply to all patients. Rather, it is meant to be used to assess systemic gaps and opportunities for improvement. For instance, we do not know whether and when in-person. post-discharge follow-up is needed for all patients, but the means to systematically and easily secure follow-up proactively for subsets of patients who do require follow-up should be in place.

The map is only meant to serve as a guide for discussing current processes of care and gaps in care. It is important that stakeholders include representatives from across the care continuum and perhaps patient representatives as well. One of the purposes of such discussions is to define a shared understanding of accountability for various aspects of the transitional care map. For example, inpatient and outpatient providers need to understand who is responsible for following tests that are outstanding at the time of discharge. A review of quality improvement methodology is beyond the scope of this review, but there are activities such as process mapping that could be used to operationalize use of this map.37

We anticipate this process would be useful for all institutions regardless of current performance on measures such as readmission rates both because such outcomes may be an imperfect measure of transitional care quality,38,39 and because an institution may still identify significant residual gaps for particular patient populations even if it has been not been identified globally as a poor performer.

### Care transitions and PACT

The value of investing in new transitional care personnel relative to harnessing the potential value of existing infrastructure and personnel is unclear. The pioneering care transitions interventions which had demonstrated reductions in readmissions had largely been patient-level interventions that predated widespread adoption of the medical home model of care, and were not extensively tested in integrated health systems.2,11 These interventions were largely constructed around a nurse (the “transitional care nurse”) or nurse practitioner dedicated to key activities to support better transitional care, such as self-management education, communication, information transfer, and follow-up care.

The literature to date has not fully explored care transitions implementation within the context of integrated systems and the medical home model. It is not clear that introducing new roles – such as the transitional care nurse – within VA is a requisite step to improving care transitions. It is important to acknowledge existing systems innovations which may already be accomplishing some of the work done in earlier transitional care interventions. For instance, with some re-engineering of the process, the PACT nurse care manager could serve as a point of contact during the peri-discharge period. Home-based primary care (HBPC), which is already widely used throughout VHA and is associated with a lower risk of hospitalization among higher-risk Veterans, could expand its role and serve as a point of continuity during the hospital-to-home transition.40 Finally, many larger VAs have structures in place, such as heart failure specialty clinics, that could identify patients during an admission and arrange close follow-up.

#### Reach-in, reach-out

The vast majority of the transitional care literature to date is hospital-centered. This is likely, at least in part, because the overwhelming focus of national policy efforts has been on reducing readmissions, and hospitals have been the entities at risk in financial penalization and public reporting initiatives. Consequently, most of the intervention literature examines models of care that essentially extend hospital services beyond hospital walls. However, it is possible that a “reach-in” model of transitions in which PACT personnel engage with patients and inpatient providers and take the “hand-off” prior to discharge would work in the VA PACT setting. Additionally, the PACT model may represent an opportunity to explore improvements in processes of care as patients transition into the hospital.

On the other hand, the more traditional transitional care models in which hospital-based personnel connect with inpatients and then follow through with them after discharge may be the right approach for hospitalized Veterans who are either not part of a PACT team, or who typically receive care at a different VA institution.

### Consider targeting high-risk populations

Given resource considerations and the lack of strong evidence suggesting benefit of transitional care programs across broad populations, it may make most sense to target more resource-intensive aspects of transitional care to higher-risk populations. There are several ways to do this. One would be to focus on specific patient populations who are generally at higher risk of poor outcomes, such as older patients and CHF patients. Another would be a referral-based system in which the clinical team uses its assessment of patient need to determine which patients to refer on to more intensive transitional care management. Finally, risk assessment using a formal risk scoring tool is yet another approach to identifying high-risk patients.

It is important to distinguish risk assessment from needs assessment. Risk assessment, as we are defining it, simply means assessing the probability that a patient with a given set of characteristics will experience a given outcome (often readmissions in this context). Needs assessment, on the other hand, refers to a patient's specific needs and can help inform the tailoring of interventions. We consider needs assessment to be an important step for all patients and one that necessarily precedes anticipatory discharge planning. Indeed, as discussed in the results section, there is good evidence that individually tailored discharge planning can help improve outcomes, especially in medical inpatients.21

The role of risk assessment tools is less clear. Many readmission risk prediction models have been tested and they have been, at best, only moderately accurate.36 Nevertheless, even models with only modest accuracy may be helpful. We are aware of at least one recent study not included in the reviews that successfully used an EMR-based risk prediction tool to identify CHF patients for inclusion in an intensive transitional care intervention.41 In addition, there may be some utility in using models to identify low-risk patients for whom intervention would not be necessary.42,43

The incremental benefits of using a formal risk prediction tool compared to clinician gestalt are unclear. The choice may depend on the intended use. Risk prediction models may be useful triage tools when trying to apply scarce resources to a large population of patients. For example, some health systems have used risk prediction scores as a way to prioritize patients for post-discharge telephone calls. Clinician referral may make more sense when considering patients for interventions – such as hospital-at-home programs or HBPC – that reach a smaller segment of the population and may need to be more nuanced in understanding patient needs and appropriateness of referral.

If a risk assessment tool is implemented in VA, it is important to consider factors such as model complexity, impact on workflow, and application to the population under consideration before broad adoption. Very simple models may perform similarly to more complex models and may be readily implemented – for example, one health system is using a single risk factor (2 or more unplanned admissions in the last year) to identify patients.44 Finally, there is no compelling reason that VA needs to consider only readmission risk prediction models. The CAN score was developed and validated in VA populations and has good ability to predict future hospital admissions or mortality.45 The incorporation of such a model into the transitional care context is another approach that could be considered, but should be studied further.

### Measure outcomes beyond 30 day readmissions

Although poor-quality care transitions can negatively impact patients' experience of care and patient safety,1-6 hospital readmissions have been the major focus of transitional care literature and policy discussions. While reduction in preventable readmissions is a laudable goal, there are many uncertainties with this outcome metric including its reliability, its relationship to care quality and mortality, and the proportion of readmissions that are ultimately preventable.38,46-48 There are other utilization measures which are often measured, but receive less attention. Emergency room utilization (especially visits that do not lead to a hospitalization) would be useful to examine in the immediate post-discharge period, especially within the context of the medical home, since theoretically some of these may be sensitive to improvements in peri-discharge care coordination. The timing of the readmissions metric likely should differ according to the group seeking to use the information to guide quality improvement. For instance, 7 day readmissions, which may be more reflective of hospital care and discharge planning, might be more relevant to VA hospitals while longer-term readmissions (and total admission rates) might be of more relevance to PACT teams.

Care transitions interventions may improve patient-perceived transitional care quality while having little impact on high-cost utilization.49 Nevertheless, improving patient experience of care may be, in and of itself, a substantive rationale for transitional care improvements. Transitions measures such as the Care Transitions Measure (CTM) which examine patient experience and their preparedness should be examined.4

Finally, care transitions also have the potential to impact patient safety. The small portion of the transitions literature that has examined patient safety outcomes has mainly focused on medicational reconciliation interventions and adverse drug event outcomes. Other outcomes such as falls, iatrogenic complications, delayed test follow-up, and missed diagnoses have not been adequately examined. While such outcomes are difficult to assess on a large scale, systematic chart review approaches such as the Global Trigger Tool could be adapted for use in the care transitions context.50

### Implementation considerations

It is probably important to think of transitional care improvements at both the patient and system level. Implementing a transitional care program – for example, the Care Transitions Intervention or Project RED – without an explicit systems-learning component could be a missed opportunity to improve sustainability, breadth, and efficiency of systematic transitional care improvements. In many VAs, there may already be personnel and structure poised to identify transitional care gaps and to work on systems improvements to address those gaps. For instance, multidisciplinary inpatient rounds involving medical providers, nursing staff, social workers, physical therapists, and nutritionists could be used as a means for anticipatory discharge planning. It is likely that such multidisciplinary discussion of patient needs will reveal larger systems gaps. Each VA needs the means to not only identify these gaps, but also to feed back the information to local and regional leaders who may be able to effect change. It might be useful to designate an individual or individuals at each institution who could be empowered to gather data about gaps from multidisciplinary team meetings and then report the information to the appropriate leadership.

Quality improvement efforts to improve cross-site communication should explicitly incorporate input from in- and outpatient providers and staff. As an example, a group of hospitalists at our own hospital has taken the initiative to visit area community-based outpatient clinics (CBOCs) and conduct semi-structured interviews to better understand primary care provider views about improving the structure, content, and timing of discharge summaries. They've found differing views among primary care providers about means and timing of admission notification, and the logistics of orchestrating “warm hand-offs”.

Dissemination of needs assessment tools could be used to guide multidisciplinary discharge planning meetings and craft individually-tailored discharge plans. VA should consider piloting the incorporation of these brief assessments and plans into cross-site communication tools such as the post-discharge telephone call template and/or the discharge summary.

Of note, it is important to anticipate some of the potential limitations of using non-VA services, such as community home nursing agencies, to accomplish care transitions since their means of communication with inpatient and outpatient VA providers (given their lack of access to the EMR) is limited and may introduce further discontinuities in care.

### Critically assess the current system of post-discharge telephone calls

There is little evidence to support the current VA practice of conducting one-time post-discharge telephone calls in broad, unselected groups of recently discharged patients. We found little evidence from published systematic reviews that simple post-discharge telephone calls improve outcomes. However, for high-risk patients with complex chronic illness and high self-management burden, periodic post-discharge contact with trained nurses may be useful. Structured telephone support interventions conducted by trained nurses have been associated with lower rates of readmissions over the long-term in CHF patients. In these populations such interventions may be a useful adjunct, and may be a more practical means of reaching larger numbers of VA patients who may be more geographically dispersed than home visit-based interventions.

Of note, the C-Trac intervention study, which was conducted in VA, was more recently published and suggested a telephone-based intervention with components bridging in- and outpatient care can improve outcomes.51 However, there are important differences between this study and the current post-discharge call system. In the C-Trac study, calls were delivered by a nurse care manager who visited with patients in the hospital, rounded with the inpatient teams, provided patients with call times and a list of red flags, and communicated findings to the primary care team. The intervention was perceived as useful by patients, and was associated with an 11% absolute reduction in readmission rates after the intervention was introduced. The intervention included only high-risk patients as defined by the presence of cognitive impairment and/or older age with other comorbidities and prior utilization. Indeed, the baseline readmission rate of this population was quite high at 34%, which is substantially higher than 30 day readmission rates in older VA and non-VA populations with serious chronic illness.9,52

Broad application of post-discharge calls may still prove useful even absent clear evidence that they reduce utilization. It is possible that such calls are viewed favorably by patients and are a useful mechanism for PACT teams to prioritize follow-up care. It is also possible that the resource use issues are relatively small since the calls are made by PACT nurses who, at any one time, may have relatively few post-discharge calls for a panel of patients. These issues need to be explored further in future work.

Finally, because post-discharge calls have become a major vehicle for transitional care in VA, it is important to consider telephone access issues. A sizable minority of patients are unreachable after discharge by phone (unpublished data from our own VISN). A given institution should look at its own post-discharge call data, assess what proportion of patients are reached, and identify reasons why some patients are unreachable. It is likely that, due to socioeconomic circumstances, some patients simply do not have access to reliable phone service. It would be important to have a system in place, then, to identify these patients prior to discharge and to have all necessary follow-up appointments secured and communicated to these patients prior to discharge.

## FUTURE RESEARCH AND QUALITY IMPROVEMENT WORK

In general, there is an overarching need for better evidence to guide selection and implementation of complex, multicomponent transitional care interventions in different settings. One of the major weaknesses of the transitional care literature is the marked variation in intervention definitions, timing of outcome follow-up, and descriptions of interventions and usual care. As the VHA conducts more research in this field, use of taxonomies (such as the ones described above) to guide study design and description may help standardize reporting. Recently, a large Patient Centered Outcomes Research Institute (PCORI) grant was awarded to better clarify which transitional care intervention components work, for whom, and in which settings based on current experience with care transitions implementation across the country. This should help fill in many of the literature gaps we've identified. In addition to this work, there are a number of more specific areas of investigation that would be relevant to the VHA:

- Readmissions in mental health care populations are very high in the VHA. There is an urgent need to better understand mental health patients' experience as they transition across setting, and to identify the facilitators and barriers to care transitions in this population. Similar work should be done in surgical populations.
- The VHA has an opportunity to think more broadly about the effects of care transitions beyond hospital readmissions. Patient surveys and qualitative work would be helpful in better understanding the types of outcomes that matter to patients.
- Adapt transitional care continuous quality improvement methods used by other initiatives for the VHA setting and populations, incorporating input from personnel across care settings and integrated with local and regional leadership.
- Even within integrated health systems like VHA, there has been relatively little examination of the communication between outpatient and inpatient care teams. There is a need to better understand communication preferences, opportunities, and priorities from both perspectives. Additionally, more work needs to be done to examine ways in which communication from the outpatient care teams to the inpatient care teams early on during a hospital admission could ease subsequent discharge planning (ie, through communication of care plans, end-of-life discussions, understanding of preference sensitive decisions).
- There are a number of comparative studies which would be helpful:
  ○ contrasting approaches to transitional care in VA patients with and without a primary VA-based medical home;
  ○ comparison of home visit-based and telephone-based interventions;
  ○ comparison of unselected and risk-prioritized approaches to post-discharge calls;
  ○ comparison of the use of electronic risk-scoring tools, disease- or age-based criteria, and clinician gestalt to identify high-risk patients for intensive transitional care management interventions; and
  ○ evaluation of changes in usual care before and after 2002 to help interpret effectiveness of studies when compared to usual care

## LIMITATIONS

Our review has a number of important limitations. Our approach to reviewing and summarizing the literature was necessarily broad rather than deep. There are many nuances in the results, internal validity, and generalizability of studies included within these reviews that are not represented in our overview. It was difficult to use established criteria to formally rate the strength of evidence for each of our conclusions, and few of the included reviews reported strength of evidence ratings. As we note in the results, our assessment of the common themes across the different reviews is likely best viewed as being based on low-strength evidence, given the indirect comparisons and the many different factors that varied among the included studies. There was heterogeneity in the outcome timings, making direct comparisons difficult. Interventions that improved short-term readmission may not have had lasting effects, whereas interventions that seemed ineffective in the short term may have longer term benefit. We only included reviews that included readmissions as an outcome as a way to feasibly scope the review and because we suspected that most interventions focused on the hospital to home transition would report this as an outcome. It is certainly possible that there are interventions that span care settings and effect care transitions that focus exclusively on other outcomes (eg, there is a body of literature focused on smoking cessation around the time of discharge).53 Furthermore, there are many outpatient-based interventions which are designed to affect emergency room and hospital utilization that are not captured in our review, but may nevertheless be important to understanding the role of care coordination in the context of the medical home.

We did not systematically update the included reviews' searches and, therefore, there are undoubtedly more recent studies that have been published that are not represented here, though we are not aware of newer studies that would substantively change our summary of findings and policy recommendations. Our recommendations are, in part, based on the evidence but also incorporate our own subjective assessment of the practical implications of the evidence (or lack thereof) and undoubtedly reflect our own clinical, research, and policy experience.

## CONCLUSIONS

The literature includes many different types of interventions, studied in varied populations and clinical settings, and implemented in different ways, but there is no commonly used taxonomy describing the various factors. Furthermore, there is very little comparative effectiveness data. It is, therefore, very difficult to identify specific intervention components and characteristics that are necessary for successful care transitions. In general, successful interventions are more comprehensive, touch on more aspects of the care transition, extend beyond the hospital stay, and are flexible enough to respond to individual patient needs. Transitional care interventions have not been well studied within integrated health systems and within the medical home context. Future work should focus on how best to incorporate outpatient teams into transitional care improvement processes.