# BACKGROUND

The hospital-to-home transition marks an abrupt shift from intensive, provider-driven care to self-managed care, and, often, from one set of inpatient providers to an entirely different set of outpatient providers. After hospital discharge, patients in both VA and non-VA settings are uncertain how to manage their health care.1-3 They are also at increased risk for adverse events,4-6 and for hospital readmissions which are common and costly.5-9 About one in 5 older Medicare beneficiaries is readmitted within 30 days of hospital discharge at an annual estimated cost of $17 billion. Similarly, 15-20% of Veterans hospitalized with higher-risk conditions such as congestive heart failure (CHF), chronic obstructive pulmonary disease, or myocardial infarction are readmitted within 30 days, while nearly one-quarter of those with chronic mental illness experiences a 30 day readmission.10 In 2011, the total cost of 30 day readmissions to the Veterans Health Administration (VHA) was $1.2 billion.10

Transitional care has been defined as “a set of actions designed to ensure the coordination and continuity of healthcare as patients transfer between different locations or different levels of care within the same location.”7 Early studies showed that nurse-led transitional care interventions beginning in the hospital and continuing after discharge had the potential to reduce the rate of hospital readmissions.2,11 Given the promise of these early interventions and several subsequent Center for Medicaid and Medicare Service (CMS) policy initiatives designed to help promote uptake of transitional care quality improvements,12,13 transitional care intervention studies have proliferated in recent years.

Currently, like many health systems, the VHA must decide how to approach care transitions. In 2010, VHA began a nationwide effort to implement a version of the medical home model of care, called Patient Aligned Care Teams (PACT), in which care coordination is a key principle.14 The VHA has also instituted a goal to have PACT nurse care managers call most patients within 2 business days of hospital discharge. There is no other broadly adopted approach to transitional care in VA settings. Further transitional care efforts might require additional investment in transitional care, but the benefits of such interventions in VA settings and for Veteran populations are not well understood.

Transitional care interventions are complex and often involve multiple components. The potential success or failure of these complex health systems interventions may depend on the nature of the interventions themselves, the settings in which they were implemented, and/or the populations included. This report aims to broadly summarize the effects of transitional care interventions in different patient populations and settings, as well as the effects of particular types of transitional care interventions on readmission rates and mortality. We also identify key themes about implementing transitional care interventions that have emerged across the literature, and provide some practical recommendations to improve care transitions in VHA and guide future research.