# REVIEWER COMMENTS AND RESPONSES

PR # | Comment | Response
Are the objectives, scope, and methods for this review clearly described?
1-8 | All reviewers entered “Yes” | Noted.
Is there any indication of bias in our synthesis of the evidence?
1-8 | All reviewers entered “No” | Noted.
Are there any published or unpublished studies that we may have overlooked?
1-3 5-7 | No | Noted.
4 | Yes - I have heard that a study was published on the IPEC Readmissions tool, and so it seems odd its not even mentioned in your compilation of studies. | Thank you for the suggestion. The IPEC tool would not be eligible for our review because it does not meet inclusion criteria for intervention type.
8 | Yes - CMAJ 2004;170(3):345-9 Adverse events among medical patients after discharge from hospital NTOCC September 2008 Update, Transitions of Care Measures, Paper by the NTOCC Measures Work Group, 2008 | Thank you for the suggestion. We examined the suggested study and determined that it does not meet inclusion criteria for intervention type.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
1 | Congratulations to the authors on a very ambitious undertaking. This is an impressive review of the literature, and a respectable attempt at deriving standardized, quantifiable and generalizable knowledge around best practices in transitional care improvement. | Noted, thank you.
1 | I agree with the author's conclusions, and believe it is supported by the reviewed material and the tables. However the clarity and potential impact of this paper is reduced by a lack of definitions or consistency for many of the terms used throughout, such as ‘intervention,’ intervention component,‘ intervention characteristic,’ ‘elements,’ and ‘population.’ I suspect that elements, components and characteristics often mean the same thing, and/or characteristics include all of the above, but there are examples where the authors seem to indicate that these terms mean something more specific, but then seem to not use them consistently for those specific meanings. ‘Characteristics’ is carefully defined as facilitator, recipient, intensity, etc in the inclusion/exclusion criteria, but there are instances in the paper that seem to imply that ‘characteristics’ is used more generally as a way of describing variation in interventions, patients and setting generally. The title to Table 2 is one example. There were many instances where I was unsure whether or not the term ‘intervention’ meant ‘intervention components,’ also called ‘key processes’ in the tables, or was referring to a named evidence-based intervention model, which is usually comprised of many components. ‘Specific populations’ sometimes seemed to mean clinical condition, sometimes demographic features, sometimes treatment setting and sometimes risk status. If all of those ways of slicing populations are what is meant by ‘specific’ it would be helpful for the authors to have said this plainly somewhere early in the paper. This is in my view exactly what much of the research in transitional care suffers from, and which is holding us back from comparative effectiveness studies, and is in fact mentioned many times in this paper, and that is a standard taxonomy. Table 2 categorizes interventions by main activities, but some are multi-component categories (eg Hospital at Home) and some are single components (f/u phone calls). This led me to be confused for the rest of the paper about what is meant by ‘intervention type.’ p 13 lns 43-45 Again interventions that are single component and some that are multi-component p 13 lns 22-25 Intervention types here is equated with processes of care, but again includes interventions that are single component or single processes, and interventions that are complex multi-component, leaving confusion about what you mean by ‘intervention’ and ‘intervention type.’ pp 13 - 15 This examines several individual components, but includes components likely included in other ‘intervention types.’ It is hard to draw conclusions from this. Although the authors do explain this, and note the difficulty deriving conclusions because of it, it leaves the reader not knowing what the authors in this paper consider to be an ‘intervention.’ p 18 first paragraph - what do the authors mean at this point by ‘intervention type’? Single conponent vs multi-component? The presence of the specific components showing promising results? | We agree that the terminology used is inconsistent and confusing. We have added definitions of intervention type, patient population, and intervention characteristics to the first paragraph of the Methods section. We have revised the rest of the report to be more consistent in the use of these terms.
1 | It would help me follow this complex paper better if the introduction included a description of the usual transitional care given in the VA, and how it is evolving - ie new activities that have been introduced for the purposes of improving care transitions and/or reducing readmissions; and the methods section began with an overview of the taxonomy problem (which is included in the results section, and is well done) with a summary of how the authors intend to define their own taxonomy for the rest of this paper. It would help ground the reader in the elements/components/characteristics that are the highest priority to examine closely, and the yardstick by which the paper intends to examine them. | We have added some VA specific information to the background, and added some definitions to the first paragraph of the methods section.
1 | METHODS - The introduction describes the method for establishing patient populations and intervention categories and references Tables 1 and 2. Table 1 makes it clear that population categories are clinical; if this is what is meant by ‘population’ throughout the rest of the paper, it would be helpful to just state that - that populations refer to patients grouped according to condition. p 17 ln 17 This refers to ‘specific populations’ and seems to mean clinical condition only. | We agree – we have revised accordingly.
1 | P 11 - I found this discussion of taxonomies very helpful, and would have found it more helpful if it had been introduced in the Methods section with a definition of terms for this paper. | Agree – included the taxonomy in first paragraph of methods.
1 | P 12 line 41 - needs closing parens | Done
1 | P 13 ln 24 ‘several show promise’ needs refs | Added
1 | p 18 ln 29 Does ‘specific intervention’ here mean components or larger multi-component models? | Revised to refer to intervention types
1 | p 18 lns25-26 ‘Variation of population’ seems awkward. Maybe ‘Variations in’ or ‘Variability of’? | Corrected
1 | P 19 - might consider adding to this list ‘Development of a standard taxonomy is desparately needed’! | Done
1 | P20 ln 30 I am assuming that the research team developed the map as a result of this review? Would be good to state that plainly. Is this based on the review alone or the combination of the review and the experience within the VA? I like the map - could be a great way to categorize components in the future. | We were more explicit in describing this as part of the review. We left in the description of specific elements used to develop the map.
1 | p 21 ln 24-25 ‘Transitional care nurse’ refers to a named comprehensive intervention model. It would be more accurate to describe this as ‘a nurse dedicated to key activities to support better transitional care.’ | We edited the “care transitions and PACT” section on page 18 (where the term is first used). We used the suggested wording after referencing the Care Transitions Intervention and we applied quotations to the term.
1 | p 25 ln 8 I am not familiar with “CBOC” | Clarified
1 | p 26 ln 41 ‘post discharge calls have become a major vehicle for transitional care aty the VA’ - it seems that this should have been introduced earlier, as one of the stated goals of this review is to determine what the VA should invest in for transitional care improvement. See my earlier comments. | As above, we added more VA-specific detail to the background including mention of current use of these calls
1 | p 27 ln 45+ There are many current initiatives doing exactly this. It might be more accurate to say ‘adapt the continuous quality imrpvement methods used by other initiatives for the VA setting and population.’ | Thank you for the suggestion – we have revised accordingly
1 | p15 ln13 ‘older Cochrane review’ - it would be helpful to put in the year this was published because the divide in effectiveness at 2002 has already been referenced. | Done
1 | p16 ln 28 In this section ‘population’ is defined a number of ways other than clinical condition - demographic factors, risk status | See comments above – we clarified that population could refer to clinical condition or demographic characteristics in Methods section
1 | Future research - Might add the need to better understand the changes in usual care before and after 2002 to help interpret effectiveness studies in the future. | Agree, added.
1 | Conclusions - I think the lack of a common taxonomy cannot be overstated, as it is on this that comparisons could be made and therefore comparative effectiveness studies be performed. | We added this to the conclusion
1 | Table 1 - The authors are clear that they did not set a timeline for readmissions as an inclusion criteria, but it would be helpful to include a column or otherwise note what the time to readmissions was for each set of reviews if possible. | We added timing information where available.
1 | Table 2 - Would help scan this table to put in bold those processes with statistically significant results. | Agree; done.
1 | Figure 2. Transitional care map - Consider adding ‘activation’ to “Patient/Caregiver education” as it is much discussed in the transitional care literature. | Added this to the description of this item, and added the term “engagement”
3 | General comments: This is a challenging literature base to synthesize; the authors appear to have captured recent systematic reviews focused on transitional care. I marked “no: for studies that were overlooked. However, I suggest that the authors make sure they are citing the most recent Cochrane review on structured telephone support/ telemonitoring interventions: Reference # 24 (“older Cochrane review” cited on page 15, line 15. I believe this was updated by the Cochrane collaboration (in 2008): http://www.thecochranelibrary.com/userfiles/ccoch/file/Telemedicine/CD007228.pdf | The study at the suggested link (Inglis 2010) was not included because it looks broadly at CHF populations, not recently discharged patients.
3 | In the background section of the main report (and ES) I could not get a sense of the scope of the readmission problem as it relates to the VA. For example, are overall readmission rates similar to rates in Medicare populations? And do the same conditions (HF, acute MI, etc…) account for similar % of total readmissions? | See earlier comment – we added VA specific readmissions information to the background section.
3 | Throughout the report, there is inconsistent use of abbreviations (particularly for CHF); for example page 14 (line 520 “congestive heart failure” is spelled out int the first sentence but no in the second. I noted a few of these cases below, but suggest word searching or having the editor check the final copy. Page 3, line 58: Consider abbreviating congestive heart failure here or adding acronym if it has not been called out previously. “CHF” is used on page 4, line 55. line 21: CHF could be used instead of spelling this out. | Done
3 | Specific comments: Preface (ii): Person listed as the PI on page i (Devan Kansagara) does not appear to be listed as an author in the “recommended citation” on page ii. I am not sure if this is an oversight? | Noted and corrected, thanks
3 | Executive Summary: page 1, first paragraph: -In line 11, I recommend that “admissions” be changed to readmission or readmission rates. | Done
3 | -The first sentence of the executive summary is not clear and maybe a little redundant. I'm not sure we can say that there has been an “exponential” increase in the implementation of transitional care programs- certainly hospitals are increasingly focused on reducing readmission rates and improving care transitions. One suggestion: “Health care systems are increasingly focused on efforts to reduce hospital readmissions; a wide variety of evidence exists on interventions to reduce readmissions, and national and local quality improvement efforts focused on transitional care have also been developed.” | This was referring to a citation showing the breadth and rapidity of program interest over a brief period of time. Nevertheless, we have reworded and appreciate the suggested language.
3 | page 2, line 14: Sentence starting with “Policy implications….” would be helpful to briefly note the variety of clinical and research experience. | The clinical and research experience of the investigators is detailed in the corresponding section of the main report – we left the details out of the executive summary in an effort to keep it relatively brief.
3 | page 3, line 40: PCMH had no effect on admissions or should this be readmissions? | Changed to readmissions
3 | page 5, line 20: Consider using readmissions (instead of rehospitalizations) for consistency. | Changed
3 | Background: page 8, line line 25-26. Are there other financial penalties besides CMS's HRRP? If not, I would specifically list this program and maybe what patient populations are covered (…unless this is not relevant to the VA). | This is less relevant to VA, but we did edit this section to note several CMS initiatives.
3 | page 8, line 32-33. See comment from ES. I'm not sure that we know enough about implementation efforts around transitional care components/programs in order to justify using “exponential.” It seems there is more of a concern about low rates of implementation, or implementation of some components (but not others) of the multicomponent interventions that are supported by the evidence. | As noted above, we changed the language accordingly.
3 | page 10, line 38. I suggest adding the specific populations (X on HF, X on acute MI…etc). | We only selected one review for each patient population or intervention type category.
3 | page 12, line 43. Parentheses is missing here. I think the sentence “They found interventions “which” should be changed to “with”? | Changed.
3 | page 13, line 15/16. Without adversely impacting which outcomes? Suggest editing this to say “…shortened length of stay without increasing readmission rates” (or whatever the outcomes were). | Specified readmissions and mortality
3 | page 13, line 16-19. Suggest not starting this sentence with the strength of evidence grade (but rather the conclusion of the study). As written, it is unclear. | Agree, changed.
3 | page 14, line 48. The sub-header here is “telephone based interventions”; I think this should be edited. The paragraph also seems to include telemonitoring interventions; maybe change to “technology based” or “Telephone-based and telemonitoring interventions.” Also, I'm not sure that this paragraph captures the uncertainty in benefit of structured telephone support vs. telemonitoring for HF in reducing early readmissions. One review cited appear to have lumped these together. Others (like ours) split them apart and found no benefit for telemonitoring (for reducing early readmissions or mortality). I believe the Cochrane review focused on outcome timings > 6 months after an index admission; if so, this should be noted. Some would say that “re”admissions > than 6 months after an index hospitalization don't have much to do with the quality of care transitions. Is there a reason why the more recent Cochrane review is not cited here? See comment above. | Agree. We have substantially revised this section and changed the subheading according. We distinguished the two interventions and noted the uncertainties in the evidence. We looked at the 2008 Cochrane review, but it did not focus on TM interventions after discharge and therefore seemed less directly applicable to our review than the reviews chosen.
3 | page 14. line 23-26: I think it may be misleading to call out this one head to head trial of telemonitoring vs. a home visit. I don't have the full review in front of me, but I think this trial may have been rated high risk of bias (and the results here are not consistent with other telemonitoring trials…). Consider editing to state that there was insufficient evidence to make a conclusion on the comparative efficacy of intervention types (or something along these lines). | Agree, changed accordingly.
3 | page 14, line 30: I was surprised to suddenly see “hospital at home” interventions. The background/methods did not make it clear that these types of interventions would be included (although I could have missed this). I think this is a different strategy than transitional care interventions; both aim to reduce utilization rates, but I think some would say that the applicability (and perhaps patient populations) are quite different and that these intervention types should not be lumped together. One focuses on an alternative to acute care, while transitional care interventions focus on a different set of processes. | We note that the purpose of these interventions was often to substitute home care for part of a hospitalization, but also note that results did not vary according to the degree of “admission substitution”. While we agree hospital-at-home interventions are probably different from other types of transitions interventions, there is substantial overlap (post-d/c home visits, pt education, bridging element) and we would argue the patient populations targeted (older patients with chronic illness) are often the same populations targeted in other TC interventions. Furthermore, these interventions are often, at least in VA, brought up in the TC discussions and are relevant to TC related policy discussions.
3 | Page 15, line 60. I'm not sure the authors of this review need to add a disclaimer about the VA trials finding an increased risk of readmissions (the sentence starting with “However….”). We don't know if these system-wide changes would have necessarily affected the results of those trials. If I remember correctly, the intervention in the trial by Oddone et. al. had some of the features of a medical home. I would just leave the sentence out, or instead add some of the reasons the authors of those trials cite as explanations for the increased rate of readmissions. | Agreed, we don't know how this would impact readmissions and there have been a number of system wide changes to all the systems studied.
3 | Page 16, line 55. Selection of higher risk populations would only increase statistical power in trials if we could correctly identify patients at higher risk. This sentence seems out of place. My sense is that trials have focused on specific populations (such as HF) because this condition itself is associated with a high proportion of Medicare hospitalizations and 30-day readmissions. And because there is some data to indicate that these readmissions are potentially preventable. The use of risk-prediction tools seems like a separate issue. | We deleted the sentence about statistical power. We clarified some of the other language in order to better distinguish the use of simple inclusion criteria from risk prediction in identifying the study population. We believe the issue is relevant to TC discussions as one of the main purported uses of risk prediction tools has been to identify patients for intervention. There has been at least one quasi-experimental study in CHF patients using a risk prediction tool to identify intervention patients. The issue comes up frequently and we believe the relative lack of empiric data examining this approach in an intervention context is worth noting.
3 | Page 19, line 55. The term “sabotage” sounds very colloquial within this report. Consider revising and focusing on quality of patient hand-off from hospital to home, or ensuring close follow-up. The terms “sabotage” and “missed” sound like there is some well defined formula that needs to be followed. | Agree, changed.
3 | Policy Implications: How would a VA hospital know that they needed to address transitional care? Is this map intended as a checklist for all hospitals to sort of inventory overall quality in transition processes. Or is intended for hospitals that have a higher than expected readmission rate for certain conditions (e.g., HRRP covered conditions)? | We anticipated it being used by all institutions regardless of current performance. We have added clarification and an explanation here.
3 | Page 21, line 45.I would be careful about using “high-risk” here. Seems like the previous section concluded that there was no evidence to support a risk-based approach to targeting patients who receive transitional care interventions. HBPC programs would certainly be able to provide in-person care following an admission for patients already enrolled. I wonder if one of the VA home-based care trials have reported data on readmission rates? If so, I would mention that here. Many VAs (or larger VAs) also have a heart failure specialty clinic that can identify patients during an inpatient admission and arrange close follow-up. | Agree – we have taken out that term and we've added a recent reference to the impact of HBPC on hospitalization rates. We appreciate the suggestion re: CHF clinics and have added this.
3 | Page 22-23; The section on risk-prediction is long (compared to other sections) given that the authors note the incremental benefits are unclear and the problems noted with implementation. Seems like this is more of a “research gap”- testing the external validity/ feasibility and effectiveness of various tools in VA settings. | While the point is well taken, we have decided to keep the section in as the question of risk assessment comes up very frequently in policy discussions and we felt it important to clarify the different approaches to risk assessment, acknowledging the gaps in evidence.
3 | Page 25, starting at page 46. I may be biased or missing some other review that found benefit, but I would disagree that using telemonitoring/transfer of physiologic data is a useful adjunct to preventing early readmissions for people with HF (without other intervention components). This paragraph seems to paint these interventions in too positive a light. | This was meant to refer to the STS interventions which were associated with long-term readmissions risk reduction. We changed the wording to emphasize the periodic contact by trained nurses (rather than the physiologic data) and we have clarified that the impact was on long-term readmissions. We have tried to be circumspect in the language, but there is at least some promising data in support of the STS interventions in CHF patients and the VA especially has reasons to value telephone-based interventions.
3 | Page 27, line 19-20. I don't think PCORI was spelled out previously in this report. | Thanks - changed
3 | Page 27, line 41-42. I'm not sure what “transition into the hospital” means. Is this about understanding the reasons for admissions? This is more challenging in some ways then looking at readmissions, and likely varies more by condition (compared with transition to home). | We edited to clarify that this is about communication between outpatient and inpatient teams at the proximal end of hospital stay – clarified that this is simply a poorly understood, but potentially important, area for further investigation. Agree it may be a challenging area to investigate, but in our opinion was still important to acknowledge.
3 | Limitations section: I would note that reviews focused on different outcome timings (and trials mentioned had different readmission outcome timings). Interventions showing efficacy at 6 months may not prevent early readmissions. | Agree, changed accordingly
4 | In general, I love your writing. I was however waiting for the big bang of what I would walk away with… everything seemed to not demonstrate a whole lot, weak evidence, so whats a reader to do? You make recommendations about a model that touches many points of care “peri discharge”, but what models do that? I know RED does, but will all your readers know that? Overall, impressive! Just know that your readers are likely well informed on transitions and will be looking for the magic pill, we don't have that, but we could offer some guidance or just make it more clear. Very proud of your work! | We acknowledge the need to provide some practical recommendations. We have strived to do this within the constraints of the available evidence. We have edited the discussion to provide some more guidance on use of the map and we have included references to documents such as the NTOCC report that detail QI strategies institutions might use. While we would have loved to be able to identify an easy answer to fixing transitional care, we simply could not find one. But we would argue a shared understanding of the current evidence base is useful in guiding future discussions, even if there are many evidence gaps.
5 | I agree that the current post-discharge calls should be critically evaluated but their purpose is not necessarily to reduce utilization or improve outcomes. This is partially addressed on p. 26, lines 28-37, but in a speculative way. Perhaps it could be clearer that this review was confined to reviews using readmissions as outcomes (in the title?) and that the conclusions reflect that focus. | We have specified our inclusion criteria in the methods. We added that our review focuses on readmissions and mortality outcomes in the objectives paragraph in both ES and main report. We also acknowledge this issue in the Limitations section.
6 | I didn't understand the attachment describing the Map you developed that facilities could use for doing a gap analysis. A little more instruction on the form would be helpful | We've added some more explanation to the corresponding section of the discussion, as well as a reference to the NTOCC report which provides greater detail about specific QI methodology.
7 | This ESP review speaks to the complexity of evaluating much of the transition literature. The lack of effectiveness of most of the interventions evaluated speaks to this complexity. This review clearly speaks to this issue. | Noted
8 | There is a noticeable paucity of discussion of metrics for transitional care. While the report calls into question the use of readmissions alone as a metric (appropriately so) it alludes to other utilization measures but not enough attention is paid to other outcome and process measures (page 23-24). Most dramatically absent is the need to assess adverse events associated with inadequate transitions. Falls with injuries, delayed or missed diagnosis due to diagnostic study results not being followed up or recommended testing not being completed, nosocomial infections, morbidity from inadequate home health arrangements, etc. do not register on the 30d readmission metric but are poor outcomes with high impact to patients and resources. There are published process measures and outcome measures in addition to utilization measures. The NTOCC (National Transitions of Care Coalition) defines various measures categories (structure, process, outcomes). This is a start but probably not the best paradigm for measuring transitional care. Additionally, the global trigger tool as a mechanism for capturing adverse events was not examined. Utilization measures (readmissions, ED visits, etc.) are based on financial outcomes for CMS first, and patient outcomes second. They are not adequate for addressing the enormity of health outcomes that suffer from inadequate transitions. Mortality is a balancing measure for readmissions. In the case of heart failure, if an institution has a high readmission rate but a lower than average mortality rate, the case can be made for enhanced access as a contributing factor. | We agree and appreciate these suggestions. We have added a discussion of patient safety to the outcomes section and added a reference to the global trigger tool.
8 | Was the SHM BOOST data included in the studies that were reviewed? BOOST data was published in 2013 and I wasn't sure if it was included in the analysis. Their emphasis on QI methodology as a way to improve transitional care is an important consideration. | We are aware of this observational study, but since this was a review of reviews we did not formally include individual studies that were not included in reviews (and this study would not have been included in recent systematic reviews most of which examined only trials). We agree that a complete discussion of TC improvement needs to acknowledge QI methods that can be used to affect change. Such a discussion is beyond the scope of this review, but we have added a sentence to the discussion about the TC map that acknowledges this gap and references the NTOCC report.