# FIGURES

FIGURE 1 LITERATURE FLOW DIAGRAM

FIGURE 2 TRANSITIONAL CARE MAP

Figure 2. This transitional care map can guide transitional care improvements, and represents the core components of an ideal transition. We suggest that many of these elements be incorporated into best practice for all care transitions. For example, practices of proactive communication, anticipatory discharge planning, patient/ caregiver communication, and timely completion of a discharge summary ought to be standard work for all patients and in any system. However, other elements, such as use of a formal readmission risk tool, detailed pharmacist-guided medication reconciliation, or reassessment of signs and symptoms after discharge via a home visit may be more important in some settings and populations. The arrows at the points of transition indicate that, in some cases, the primary care team may be able to “reach-in” to the hospital as a means of care coordination.

Advanced care planning around goals of care at the end of life can be an important part of transitional care from primary care to the hospital, and in particular among patients with terminal illness or geriatric patients, can be initiated in the primary care setting and help guide inpatient care decisions, or potentially avoid unwanted admission altogether. Similarly, if a change in functional status is anticipated after a planned hospitalization – for example, after planned hip replacement – decisions around choice of skilled nursing facilities and other post-discharge needs might be best coordinated prior to hospitalization.

Proactive Communication in which the hospital team alerts primary care that a patient is hospitalized, and in which, key history from the primary care setting is communicated forward to the hospital team. A well-integrated and complete medical record may be sufficient in most circumstances. However, where systems are less integrated or where more complex medical or social factors are at play, a warm handoff from primary care to hospital providers can be beneficial.

Anticipatory discharge planning is a key element of all hospital-to-home transitions. We suggest that all team members – including physicians, inpatient nurses, social workers, physical and occupational therapists, as well as family and caregivers – are supported to anticipate and prepare for post-discharge needs such as durable medical equipment, home health, and transportation. Multidisciplinary meetings conducted during inpatient rounds may be an efficient way to accomplish much of this discussion.

Readmission risk assessment for the purposes of identifying patients for transitional care interventions can be performed at admission, discharge, or even in the post-discharge period depending on the nature of the intervention. For example, some interventions incorporate length of stay as a variable, and thus would be performed on discharge and are best used to guide post-discharge interventions. Other interventions are intended to begin during hospitalization, and thus are best performed early on hospitalization. See Policy Implications section for more discussion of risk assessment.

Psychosocial needs assessment should assess factors such as access to outpatient care, ability to afford needed medications, health literacy and numeracy, housing, transportation, and social/caregiver support. These factors inform a more accurate understanding of a patient's ability to self-manage care after hospitalization, whether caregivers should be involved in self-management education, and should guide decisions around role for home health or skilled nursing placement, complexity of medication regimens, and any additional transitional care needs that patient's might need to be successful after hospitalization.

Communication with hospital and ambulatory providers during hospitalization may be important at key junctures, for example, around end of life decision-making or around prescribing opioids in high-risk situations, where the success of the plan hinges on the patient's outpatient providers and care environment.

Patient/ Caregiver engagement and education should occur throughout hospitalization and utilize teach-back to assess patient understanding. Education can be tailored to focus on transitional care pillars which include: patient understanding of self-management including red flags and warning signs that should prompt further medical attention, medication changes, and a clear follow-up plan. These activities are an opportunity to improve patients' self-efficacy and confidence in self-management, as well as empowering them to serve as their own advocates while transitioning across care settings.

DC summaries should be completed within a reasonable time frame of discharge (some suggest within 24 hours of discharge), should be complete, and transmitted effectively to appropriate outpatient providers. Some key elements of discharge summaries include hospital course and discharge diagnoses, an accurate medication list with rationale for new or discontinued medications, results of key procedures, pending studies and any suggested next steps in evaluation, follow up appointments, discharge location (ie, home, name of SNF), suggested next steps in evaluation, and a physical examination that includes cognitive and functional status.

Patient-level transition record might vary depending on the system and patient. All patients should receive basic written instructions that include an accurate medication list and clear instructions to stop or start any medications and self-care instructions that avoid overly complex language. Some patients may benefit from additional written materials such as a pictorial medication calendar or a more detailed personal health record. For some high-risk populations (eg, CHF patients), there may be some utility in creating (or vetting existing) educational tools/instructions, many elements of which may be applicable to most patients, and which can have sections that are individually adaptable as well.

Medication reconciliation, while not supported by literature to reduce readmission rates, is an expected part of any hospital admission and discharge. Depending on patient risks and medication complexity and existing resources this may best be performed by a pharmacist versus an inpatient provider.

Reassessment of signs and symptoms: optimal approaches to reassessing signs and symptoms after discharge may depend on system and patient characteristics. For example, there is some evidence that a home visit after discharge can improve care and reduce readmissions among high-risk patients, however it is neither feasible nor cost effective for all patients to receive a home visit after discharge. Similarly, systems best consider who performs a phone call after hospitalization (perhaps primary care teams, to assure a close connection back to primary care, or perhaps the health plan to assure that all medications and equipment have been supplied, and to expedite approval and scheduling of any needed appointments).

Ambulatory follow up: the optimal timing for post-discharge follow-up is unclear and likely differs based on patient need and medical acuity.

Outstanding test follow through: errors due to lack of follow through on tests (lab, imaging, pathology) pending at the time of discharge are common. It is important that there is a shared understanding of accountability for test follow-through among outpatient and inpatient care teams, and a seamless process for communicating outstanding tests and responsibility for follow through across care settings.