# SEARCH STRATEGY

Concept | Search string
recurrence | “recurrence”[MeSH Terms] OR “recurrence”[All Fields]
recurrences | “recurrence”[MeSH Terms] OR “recurrence”[All Fields] OR “recurrences”[All Fields]
hospital-based home care | “home care services, hospital-based”[MeSH Terms] OR (“home”[All Fields] AND “care”[All Fields] AND “services”[All Fields] AND “hospital-based”[All Fields]) OR “hospital-based home care services”[All Fields] OR (“hospital”[All Fields] AND “based”[All Fields] AND “home”[All Fields] AND “cares”[All Fields])
eHealth | “telemedicine”[MeSH Terms] OR “telemedicine”[All Fields] OR “ehealth”[All Fields]
telehealth | “telemedicine”[MeSH Terms] OR “telemedicine”[All Fields] OR “telehealth”[All Fields]
telemedicine | “telemedicine”[MeSH Terms] OR “telemedicine”[All Fields]
continuity | “Continuity”[Journal] OR “continuity”[All Fields]
referral | “referral and consultation”[MeSH Terms] OR (“referral”[All Fields] AND “consultation”[All Fields]) OR “referral and consultation”[All Fields] OR “referral”[All Fields]
discharge | “patient discharge”[MeSH Terms] OR (“patient”[All Fields] AND “discharge”[All Fields]) OR “patient discharge”[All Fields] OR “discharge”[All Fields]
sub-acute care | “subacute care”[MeSH Terms] OR (“subacute”[All Fields] AND “care”[All Fields]) OR “subacute care”[All Fields] OR (“sub”[All Fields] AND “acute”[All Fields] AND “care”[All Fields]) OR “sub acute care”[All Fields]
subacute care | “subacute care”[MeSH Terms] OR (“subacute”[All Fields] AND “care”[All Fields]) OR “subacute care”[All Fields]
cochrane database syst rev[ta] | “Cochrane Database Syst Rev”[Journal]
acp journal club[ta] | “ACP J Club”[Journal]
health technol assess[ta] | “Health Technol Assess”[Journal]
evid rep technol assess summ[ta] | “Evid Rep Technol Assess (Summ)”[Journal]
evidence-based medicine[mh] | “evidence-based medicine”[MeSH Terms]
behavior and behavior mechanisms[mh] | “behavior and behavior mechanisms”[MeSH Terms]
therapeutics[mh] | “therapeutics”[MeSH Terms]
risk[mh] | “risk”[MeSH Terms]
death | “death”[MeSH Terms] OR “death”[All Fields]
treatment outcome[mh] | “treatment outcome”[MeSH Terms]
Humans[Mesh] | “humans”[MeSH Terms]
adult[MeSH] | “adult”[MeSH Terms]

Database: PubMed

Date of search: 5/02/2014

Filters activated: Humans, English, Adult: 19+ years

User query: ((((((((“Recurrence”[Mesh]) OR “Patient Readmission”[Mesh])) OR ((((readmission) OR readmissions) OR recurrence) OR recurrences))) AND ((((((((((((((((((((((((((((((((((((((“exercise therapy”) OR “physical therapies”) OR “physical therapy”) OR “non-professional home care”) OR “nonprofessional home care”) OR “home nursing”) OR “hospital-based home cares”) OR “hospital-based home care”) OR “hospital home care services”) OR “hospital based home cares”) OR “mobile health”) OR eHealth) OR telehealth) OR telemedicine) OR “clinical pathways”) OR “clinical pathway”) OR “clinical paths”) OR “clinical path”) OR “critical paths”) OR “critical path”) OR “critical pathway”) OR “critical pathways”) OR continuity) OR referral) OR discharge) OR sub-acute care) OR subacute care) OR posthospital*) OR post-hospital*) OR postacute care) OR post-acute care) OR coordinate) OR coordination) OR post-discharge) OR postdischarge) OR transition*)) OR (((((((((((“Case Management”[Mesh]) OR “Rehabilitation”[Mesh]) OR “Continuity of Patient Care”[Mesh]) OR “Patient Discharge”[Mesh]) OR “Patient Transfer”[Mesh]) OR “Telemedicine”[Mesh]) OR “Critical Pathways”[Mesh]) OR “Home Care Services, Hospital-Based”[Mesh]) OR “Home Nursing”[Mesh]) OR “Physical Therapy Modalities”[Mesh]) OR “Exercise Therapy”[Mesh]))))) AND (((systematic review[ti] OR meta-analysis[pt] OR meta-analysis[ti] OR systematic literature review[ti] OR (systematic review[tiab] AND review[pt]) OR consensus development conference[pt] OR practice guideline[pt] OR cochrane database syst rev[ta] OR acp journal club[ta] OR health technol assess[ta] OR evid rep technol assess summ[ta] OR drug class reviews[ti]) OR (clinical guideline[tw] AND management[tw]) OR ((evidence based[ti] OR evidence-based medicine[mh] OR best practice*[ti] OR evidence synthesis[tiab]) AND (review[pt] OR diseases category[mh] OR behavior and behavior mechanisms[mh] OR therapeutics[mh] OR evaluation studies[pt] OR validation studies[pt] OR guideline[pt] OR pmcbook)) OR ((systematic[tw] OR systematically[tw] OR critical[tiab] OR (study selection[tw]) OR (predetermined[tw] OR inclusion[tw] AND criteri*[tw]) OR exclusion criteri*[tw] OR main outcome measures[tw] OR standard of care[tw] OR standards of care[tw]) AND (survey[tiab] OR surveys[tiab] OR overview*[tw] OR review[tiab] OR reviews[tiab] OR search*[tw] OR handsearch[tw] OR analysis[ti] OR critique[tiab] OR appraisal[tw] OR (reduction[tw] AND (risk[mh] OR risk[tw]) AND (death OR recurrence))) AND (literature[tiab] OR articles[tiab] OR publications[tiab] OR publication[tiab] OR bibliography[tiab] OR bibliographies[tiab] OR published[tiab] OR unpublished[tw] OR citation[tw] OR citations[tw] OR database[tiab] OR internet[tiab] OR textbooks[tiab] OR references[tw] OR scales[tw] OR papers[tw] OR datasets[tw] OR trials[tiab] OR meta-analy*[tw] OR (clinical[tiab] AND studies[tiab]) OR treatment outcome[mh] OR treatment outcome[tw] OR pmcbook)) NOT (letter[pt] OR newspaper article[pt] OR comment[pt]))) AND (Humans[Mesh] AND English[lang] AND adult[MeSH])

## ADDITIONAL SEARCH FOR PATIENT CENTERED MEDICAL HOME

Database: PubMed

Date of search: 8/27/2014

User query: ((((medical home[Title]) OR medical homes[Title]) OR pcmh[Title])) AND “Patient-Centered Care”[MeSH] AND (systematic[sb])