# TABLES

Table 1 Characteristics and Key Findings of Systematic Reviews of Care Transitions, by Patient Population

Patient condition; Systematic review; Search dates | N controlled trials (total N studies) | Sample characteristics; N total from RCTs (Tx + control) | Summary estimate for readmission risk (95% CI) | Summary estimate for mortality (95% CI) | Quality measures
Acute MI/ Acute Coronary Syndrome Auer, 2008^34^ 1966-2007 | 16 controlled trials, including 14 RCTs (26 studies total) | Hospitalized for ACS including unstable angina, NSTEMI, STEMI N=2467 from trials, including N=1910 from RCTs | 6-12 months: 0.96 (0.79-1.17) | All causes: 0.94 (0.63-1.40) All causes at 1 year: 0.94 (0.63-1.44) | Study quality for RCT assessed using modified Jadad score 3 (lowest ROB category): n=8 2: n=5 1 (highest ROB category): n=3 Before-after designs: n=12 (no formal ROB assessment)
Cancer Smeenk, 1998^54^ 1985-1997 | 5 RCTs (9 studies total) | Cancer N=4249 | Range of ratios for readmission (%) in intervention group/control group: 0.62 to 1.12 Combined estimate NR. Timing of readmission assessment NR. | NR | Weighted methodological quality score (0-100 max): 48: n=1 50: n=1 56: n=1 61: n=1 63: n=1 64: n=2 68: n=1 All considered moderate quality
CHF Feltner, 2014^19^ 1990-2013 | 47 RCTs (47 studies total) | Moderate-to-severe HF; mean age of 70 N=8693 | Combined RR (95% CI) by intervention type; results from single studies per intervention type not included below: Home-visiting program, 3-6 months: 0.75 (0.66-0.86) Structured telephone support, 3-6 months: 0.92 (0.77-1.10) Telemonitoring, 3-6 months: 1.11 (0.87-1.42) Clinic-based (MDS-HF), 6 months: 0.70 (0.55-0.89) | Combined RR (95% CI) by intervention type; results from single studies per intervention type not included below: Home-visiting program, 3-6 months: 0.77 (0.60-0.996) Structured telephone support, 3.6 months: 0.69 (0.51-0.92) Clinic-based (MDS-HF) 6 months: 0.56 (0.34-0.92) | AHRQ ROB for trials (high, medium, low, unclear) Low ROB: n=6 Medium ROB: n=27 High ROB: n=9 Unclear ROB: n=5
COPD Prieto-Centurion, 2014^24^ 1966-2013 | 5 RCTs (5 studies total) | Patients hospitalized for COPD within the previous 12 month. N=1393 | 2 studies found reduced 12-month readmissions (mean number of hospitalizations per patient, 1.0 vs 1.8;P = 0.01; percent hospitalized, 45 vs 67%;P= 0.028) 3 studies found no significant change in 6 or 12-month readmissions. | 4 of 5 studies: no difference 1 study: increased 12-month mortality (17 vs 7%, p=0.003) | EPOC criteria (# domains with low ROB: 1-7 max) 6: n=4 5: n=1
General/unselected Leppin, 2014^18^ 1990-2013 | 42 RCTs (42 studies total) | N=17273 | 30 days: 0.82 (0.73-0.91) | NR | EPOC ROB (high, low, unclear) “Most studies were at overall low risk of bias. The most common methodological limitation of these trials was the lack of a reliable method for dealing with missing data.” 8/42 studies were rated as low ROB in all categories; all others were rated as high or unclear ROB in one or more categories.
Mental Health Vigod, 2013^55^ Database inception through 2012 | 13 controlled trials, including 8 RCTs (15 studies total) | Admitted to the hospital for mental health inpatient care N=2880 (Controlled trials) N=1007 (RCTs) | Range among studies in % of patients readmitted, intervention group vs control: 3 month: 7-23 vs 13-36 6-24 month: 0-63% vs 4-69% | NR | EPOC criteria (# domains with low ROB: 1-9 max) 8: n=1 7: n=1 6: n=1 5: n=4 4: n=3 3: n=3 Most included studies had small sample sizes, high dropout rates, and/or did not account for baseline differences between groups on key prognostic factors.
Stroke Prvu-Bettger, 2012^20^ 2000-2012 | 24 RCTs stroke 8 RCTs MI (44 studies total: 27 stroke, 17 MI) | hospitalized for stroke or acute coronary syndromes N=4307 stroke N=1062 MI | Insufficient evidence for most intervention subtypes in both stroke and MI. Moderate strength evidence that hospital-initiated support did not reduce readmissions in stroke patients. Timing of readmission assessment NR. | Low strength evidence in MI patients: reduced 3 month mortality (1 study), reduced 12 month mortality (2 studies) | AHRQ (Good, Fair, Poor Quality) Good: n=10 Fair: n= 42 Poor: n=10 Strength of evidence insufficient for all intervention/population subgroups except as noted.

Abbreviations: ACS = acute coronary syndrome; AHRQ = Agency for Healthcare Research & Quality; CHF = congestive heart failure; CI = confidence interval; COPD = chronic obstructive pulmonary disease; EPOC = Cochrane Effective Practice and Organisation of Care Group; HF = heart failure; MDS-HF = multidisciplinary heart failure; MI = myocardial infarction; N = population/study sample size; NR = not reported; NSTEMI = non-ST-segment elevation myocardial infarction; RCTs = randomized controlled trials; ROB = risk of bias; STEMI = ST-segment elevation myocardial infarction; Tx = treatment; vs = versus

Table 2 Characteristics and Key Findings of Systematic Reviews of Care Transitions, by Intervention Type

Key process; Systematic review; Search dates | N controlled trials (total N studies) | Sample characteristics; N total from RCTs (Tx + control) | Summary estimate for readmission risk (95% CI) | Summary estimate for mortality (95% CI) | Quality measures
Geriatric Case Management Huntley, 2013^56^ 1950-2010 | 11 RCTs (11 studies total) | Patients aged 65+ who were discharged from acute care hospitals (ED included) or were community dwelling N=4318 | 0.71 (0.49-1.03) | Combined estimate NR. Mortality (5 studies) was not significantly different based on case management. | Cochrane ROB “Risk of bias was generally low”. Most studies had low or unclear ROB in all categories except one study which had high ROB in 3 categories.
Geriatric Case Assessment Ellis, 2011^35^ 1966-2010 | 22 RCTs (22 studies total) | Adults aged 65 years or older who were admitted to the hospital. N=10,315 | No difference between groups, N=3822. OR 1.03 (0.89-1.18) | Death or functional decline, combined outcome: 0.76 (0.64 to 0.90, P=0.001) based on data from 5 RCTs, N= 2622 | Cochrane ROB “The studies identified were heterogeneous in quality. All used some method of individual patient randomization, though reporting of key issues such as allocation concealment varied. Outcome assessment was seldom blinded [though] this is less of an issue for hard outcomes such as death or institutionalization”. Some trials noted attrition for functional or cognitive outcomes.”
Discharge planning Shepperd, 2013^21^ 1946-2012 | 24 RCTs (24 studies total) | Mostly older medical patients, but some trials included a mix of medical and surgical conditions. Psychiatric patients were included as well. N=8,098 | Within 3 months of discharge: 0.82 (0.73-0.92) for older patients with a medical condition. No difference was found when mixed medical and surgical populations were included. | At 6-9 months: 0.99 (0.78-1.25) | Cochrane ROB, Low ROB: n=9 Medium ROB: n=9 High ROB: n=5 Unclear ROB: n=1
ERAS/Fast Track Kagedan, 2014^57^ 2000-2013 | 0 trials or RCTs (10 studies total) | After pancreatic surgery N=0 (no RCTs) | Range among studies in % of patients readmitted, ERAS vs UC: (3.5-15) vs (0-25) | Range (% of patients), ERAS vs UC: (0-4) vs (0-3) | GRADE (Low; Moderate; High) “No high-quality studies were identified. Cohort studies comparing multiple groups were labelled as being of moderate quality. Single-group prospective studies were graded as low quality.” Moderate quality: n=7 Low quality: n=3
Hospital at home Caplan, 2012^22^ Database inception through 2012 | 61 RCTs (61 studies total) | N=6992 | 0.75 (0.59-0.95) | 0.81 (0.69-0.95) | EPOC criteria Quality ratings not reported; “Almost all studies were not blinded. However, many studies used blinded initial assessments before randomisation. Some outcome assessment was blinded.”
Medication reconciliation Kwan, 2013^23^ 1980-2012 | 5 RCTs (18 studies total) | N=1075 | ER visits and hospitalizations within 30 days of discharge in 3 RCTs, HR 0.77 (95% CI, 0.63-0.95) | NR | Cochrane ROB Low ROB: n=5 RCTs
PCMH Jackson, 2013^58^ Database inception through June 2012 | 9 RCTs (19 studies total) | Unselected population N=54465 | 0.96 (0.84-1.10) | NR | AHRQ (Good, Fair, Poor Quality). All but one study were rated as being good or fair quality.
Telemonitoring and structured telephone support Pandor, 2013^26^ 1999-2011 | 21 RCTs (21 studies total) | Heart failure N=6317 | Median HR (credible interval, 2.5%-97.5%) vs UC. All-cause: STS HH: 0.97 (0.70-1.31) TM office hours (transmitted data reviewed by medical staff during office hours): 0.75 (0.49-1.10) HF-related: STS HH: 0.77 (0.62-0.96) TM office hours: 0.95 (0.70 1.34) | Median HR (credible interval, 2.5%-97.5%) vs UC: STS HH vs UC: 0.77 (0.55-1.08) TM office hours vs UC: 0.76 (0.49-1.18) | Study quality not reported individually; “The methodological quality of the 21 included studies varied widely and reporting was generally poor on random sequence generation, allocation concealment, blinding of outcome assessment, definition and confirmation of HF diagnosis, and intention-to-treat analysis.”
Telephone follow-up, primary-care based Crocker 2012^29^ 1948-2011 | 3 RCTs (3 studies total) | Unselected population N=1765 | Combined estimate NR. None of the 3 RCTs reported a statistically significant impact of telephone follow-up on readmission or ER visits. | NR | Study quality not reported individually: assessed sequence generation, allocation concealment, blinding, follow-up and intent to treat analysis, and publication bias. Most studies were high or unclear ROB based on poor reporting of sequence generation, allocation concealment; lack of blinding; and lack of information about attrition.
Telephone follow-up, hospital-based Mistiaen, 2006^28^ Database inception through July 2003 | 13 RCTs (33 studies total) | Unselected population with cardiac and surgical subgroup analyses N=5110 | Cardiac (3 RCTs, N=616): 0.75 (0.41-1.36) Surgical (4 RCTs, N=460): 0.65 (0.28-1.55) | NR | Cochrane ROB Medium ROB: n=7 High ROB: n=26

Abbreviations: AHRQ = Agency for Healthcare Research & Quality; CI = confidence interval; ED = emergency department; EPOC = Cochrane Effective Practice and Organisation of Care Group; ER = emergency room; ERAS = enhanced recovery after surgery; GRADE = grading of recommendations assessment, development and evaluation; HR = hazard ratio; N = population/study sample size; NR = not reported; OR = odds ratio; RCTs = randomized controlled trials; ROB = risk of bias; STS HH = structured telephone support delivered by human-to-human contact; TM = telemonitoring; Tx = treatment; UC = usual care; vs = versus

Table 3 Clinical Outcomes, Utilization Outcomes, and Implementation Considerations in Systematic Reviews of Care Transitions, by Patient Population

Patient population Systematic review; Search dates | Clinical outcomes | Other utilization outcomes | Implementation considerations | Limitations/comments
Acute MI/Acute Coronary Syndrome Auer, 2008^34^ 1966-2007 | Re-infarction rates RR 0.51, 95% CI 0.23 – 1.13 among trials) Smoking cessation RR 1.29 (1.02-1.63, I2 = 66%) | NR | Interventions that included provider- or systems-level components reduced mortality (RR 0.77, 95% CI 0.65-0.92) whereas patient-level interventions did not (RR 0.93, 95% CI 0.63-1.36). However, many of the studies of provider- or systems-level interventions were before-after studies. Interventions targeting an increase in the use of effective medications were associated with mortality benefit (RR 0.80, 95% CI 0.68-0.93) whereas those not targeting medication use were not (RR 0.75, 95% CI 0.39-1.46). | Substantial statistical and clinical heterogeneity among studies. Nearly half the included studies were before-after studies and these accounted for most of the benefit seen [mortality clinical trials only RR was 0.96 (0.64-1.44) vs 0.77 (0.66-0.9) for before-after designs] All studies were published 2005 and earlier; applicability to current practice is uncertain.
Cancer Smeenk, 1998^54^ 1985-1997 | Quality of life outcomes were positively associated with home care programs in 3 of 7 studies. | NR | Programs that included multidisciplinary team meetings and involvement of team members during patient home visits was associated with favorable outcomes in 3 studies. | Author notes: The methodological quality of the studies was moderate (median score of 62/100). The main shortcomings were in the areas of population homogeneity, study design, comparability of groups, handling of drop outs, and blinding procedures. Furthermore, the findings of failed to show a consistent pattern across studies
CHF Feltner, 2014^19^ 1990-2013 | NR | NR | The following types of interventions had no effect on mortality: telemonitoring, nurse-led clinics, and primarily educational intervention. (low SOE) Evidence was insufficient for primary care interventions and cognitive training programs. | Minimal 30 day data. UC not well defined and quite variable. Conclusions of this study and the NHS one focusing on TM/STS reach different conclusions with slightly different study inclusion.
COPD Prieto-Centurion, 2014^24^ 1966-2013 | NR | NR | Author states: No specific intervention or bundle of interventions could be identified as effective in reducing the rate of rehospitalizations. | Well done systematic review with a focus on readmission. Studies that did not have readmission as the primary outcome were excluded. No studies were found that examined 30-day readmission as a primary outcome, all used either 6 or 12 months. Some studies initiated interventions >28 days after the patient was discharged. Extensive heterogeneity in both the content and context of the intervention.
General/unselected Leppin, 2014^18^ 1990-2013 | NR | NR | Characteristics of the intervention such as impact on patient workload and the site of delivery had no significant effect. | Adjusted for year of publication
Mental Health Vigod, 2013^55^ Database inception through 2012 | NR | NR | Study author identified the following as effective components within the context of multicomponent interventions: pre-discharge medication education/reconciliation; post-discharge telephone follow-up, efforts to ensure timely follow-up appointments, home visits and peer support, bridging components of transition manager; and timely communication by in-patient staff with an outpatient care or community service provider during transition. | These results are consistent with the 2 other MH reviews.
Stroke Prvu-Bettger, 2012^20^ 2000-2012 | No significant differences in ADLs (7 studies using the Barthel index). Insufficient evidence on caregiver outcomes (inconsistent effects on caregiver strain, quality of life in 5 studies measuring caregiver outcomes) | NR | Insufficient evidence of benefit of patient and family educational interventions (5 studies), community based support (10 studies), and chronic disease management (2 studies). | Limitations of the studies include sample size, heterogeneity of outcome measures, lack of definition for the UC group, and fair or poor study quality. Authors cite the need for definitive taxonomy for the components of transitional care services and the evaluation of outcome measures.

Abbreviations: ADLs = activities of daily living; CHF = congestive heart failure; CI = confidence interval; COPD = chronic obstructive pulmonary disease; MH = mental health; MI = myocardial infarction; NR = not reported; RR = relative risk; SOE = strength of evidence; UC = usual care

Table 4 Clinical Outcomes, Utilization Outcomes, and Implementation Considerations in Systematic Reviews of Care Transitions, by Intervention Type

Key process; Systematic review; Search dates | Clinical outcomes | Other utilization outcomes | Implementation considerations | Limitations/comments
Geriatric Case Management Huntley, 2013^56^ 1950-2010 | NR | ED visits, GP visits, specialist clinic/outpatient visits and length of stay were not improved by case management in all but one study. | Case management initiated in hospital (2 RCTs) was associated with decreased readmissions; 3 out of 4 RCTs showed no difference for case management initiated upon discharge; 5 RCTs on case management initiated in the community showed no significant differences in readmissions. | 4 other case management systematic reviews report similar findings: some limited examples of positive results, but overall non-significant effects.59-62
Geriatric Case Assessment Ellis, 2011^35^ 1966-2010 | There was a significant reduction in cognitive function (5 trials, 3317 participants, standardized mean difference 0.08, 0.01 to 0.15, P=0.02) associated with CGA. There were non-significant differences for dependence. | The hospital costs of CGA 5 intervention were mixed – some trials reported decreased cost while others reported increased cost. Few trials accounted for nursing home costs; those that did suggested that CGA might be associated with overall reduced cost. | The positive impact on living at home was seen only in studies of CGA wards and no among studies of mobile CGA consultative teams (interaction χ^2^ = 9.06, p = 0.003). There is only evidence supporting CGA assessment in setting of geriatric wards, and not for consultative teams. The authors speculate that specialized wards allow nursing and other key personnel to develop skills and expertise and foster multi-disciplinary team-building, while consulting teams might have difficulty in influencing health provider behavior. | Author notes: Trials evaluating direct admission from ED all have admission criteria related to age, whereas trials evaluating post-acute care all have criteria related to needs (with one trial as an exception). Author suggests that the optimal model of comprehensive geriatric assessment for hospitals includes both acute and post-acute models.
Discharge Planning Shepperd, 2013^21^ 1946-2012 | CHF patients improved on total CHFQ score in one trial: mean difference 22.1 (20.8), p<0.01; whereas, control patients in a trial of stroke patients had more functional improvement on the Barthel score (2 points change in tx vs 6 points change in controls, p<0.01). QOL outcomes were mixed among studies. No difference between groups in 5 trials that reported functional status, mental well-being, perception of health, self-esteem, and affect. | LOS after medical admission was lower with discharge planning vs UC: mean difference in 10 trials -0.91 days (95%CI -1.55 to -0.27) in 10 trials. LOS after surgery did not differ: mean difference in 2 trials -0.06 days (95%CI -1.23 to 1.11). | The point during admission when discharge planning may have bearing on timely follow-up. Discharge planning was implemented varied across studies: commencing from time admission in 2 trials, 3 days prior to discharge in one study. | Very good review that looked at a wide range of trials including a diverse group of patients. Significant heterogeneity existed between trials with regards to specific interventions. Some interventions were not well described, making comparisons between trials difficult.
ERAS/Fast Track Kagedan, 2014^57^ 2000-2013 | NR. | Four studies examined costs associated with postoperative care following pancreatic surgery. Two of these studies found a decrease in cost following the implementation of an ERAS protocol and 2 studies found no significant change. | NR | This review focused on pancreatic surgery, and notes that, “Although randomized trials and meta-analyses have consistently reported an advantage to ERAS over conventional care, these studies have been performed predominantly in colorectal surgery patients.”
Hospital at home Caplan, 2012^22^ Database inception through 2012 | No meta-analysis was performed for patient or caregiver satisfaction because varied instruments were used, but studies consistently found higher satisfaction in HAH groups (21/22 studies reporting patient satisfaction, 6/8 studies reporting CG satisfaction). No difference in caregiver burden (7 studies, mean difference 0.00, 95% CI -0.19 to 0.19). | Mean cost difference HAH vs UC (11 RCTS): -1567.11 (- 2069.53 to -1064.69, p<0.001) Average cost savings 26.5%. 32 of 34 studies reporting any cost data concluded HAH was less expensive. | Mortality, readmission, and cost findings were consistent across all subgroups (type of hospitalization, degree of admission substitutions, average age of patient, and year of publication). Components of HAH programs are not described at all; the only criterion seems to have been home-based care substitution. | Specific components of any of the HAH intervention are not well-described. Periods of observation for mortality and readmissions were not defined and likely varied significantly. “Next best” review has differing conclusions: Cochrane review from 2009 of HAH to facilitate early discharge (as opposed to HAH to replace admission) found no clear difference in mortality in stroke (HR 0.79 [0.32—1.91]) or mixed elderly (HR 10.6 [0.69—1.61]), and they found higher readmissions among the elderly (HR 1.57 [1.10—2.24]). They did find lower rates of residential care and greater satisfaction, with cost data mixed.
Medication Reconciliation Kwan, 2013^23^ 1980-2012 | Fewer adverse drug events occurred in 2 studies, respectively: Tx vs control: 1% vs 11% (p=0.01) RR 0.72 (95% CI 0.52 to 0.99) | NR | NR
PCMH Jackson, 2013^58^ Database inception through June 2012 | One observational study reported a higher rate of improved HbA1c and LDL cholesterol in tx patients. Another obs. study found no difference in composite diabetes and CAD outcomes. None of the 3 RCTs found differences in self-reported health status. One observational study found less functional decline with PCMH at 1-year follow-up (31% vs 49% of patients). | Three RCTs reporting ED utilization found no effect: combined RR 0.93 (95% CI 0.72 to 1.20). | NR | The components, models, and operationalization of PCMH varied widely among studies.
Telemonitoring Pandor, 2013^26^ 1999-2011 | Quality of life was significantly improved in 3 of 4 studies of STS interventions, and 2 of 4 studies of TM interventions that measured and reported it. | HF-related hospitalizations: STS HM vs UC: 1.02 (0.70-1.49) STS HH vs UC: 0.76 (0.61-0.94) TM office hours vs UC: 0.86 (0.61-1.21). LOS was reported in 6 studies but unaffected in 5 of them (shorter in Tsuyuki et al, 2004). | In the 5 studies that reported it, adherence to RM was good (STS 55-84%, TM 81-98%). Likewise, reported acceptance and/or satisfaction rates were high in 5 of 6 studies. In the sixth, however (Scherr, 2009), 16/66 patients in the intervention group either did not transmit any data or requested early termination. Since RM cannot affect outcomes unless actions are taken based on results of monitoring, any successful intervention also requires patient education/empowerment and advice/timely access to care. Studied interventions were heterogeneous in terms of monitored parameters and HF selection criteria, and results were not reported in such a way as to permit assessment of intervention effect modifiers. Thus, uncertainties remain around best “active ingredients” of RM interventions, suitability of different systems, and determinants of patient responsiveness. Finally, RM is likely to have greater impact in systems where UC is suboptimal and HF readmission rates are high. | This is limited to HF patients and cannot be extrapolated to other patient populations. The authors intended to use meta-regression to explain heterogeneity in effects between studies but could not because of limited data on study-level covariates.
Telephone follow-up, Primary-care based Crocker 2012^29^ 1948-2011 | NR | In all 3 included studies, primary care contact improved with post-discharge telephone follow-up. 2 studies examining ED visits showed no effect. | NR | Search may have overlooked relevant studies held in other databases.
Telephone follow-up, Hospital-based Mistiaen, 2006^28^ Database inception through July 2003 | Anxiety in cardiac surgery patients 1 month post-discharge was not significantly different. Tx vs UC, pooled effect from 3 studies: standardized mean difference -0.47 (95% CI -1.28 to 0.34) Depression was not significantly different between tx and control in 2 studies. | ED visits in surgery patients was not significant. Pooled from 2 studies, tx vs control: RR 1.47 (95% CI 0.85 to 2.53) | NR | Most of the included studies were poor quality (high ROB) and small sample size. The authors cite clinical diversity and statistical heterogeneity among studies as further limitations. They note, however, that patients valued the TFU calls despite no detectable benefits in the measured empirical outcomes.

Abbreviations: CAD = coronary artery disease; CGA = comprehensive geriatric assessment; CHF = congestive heart failure; CHFQ = chronic heart failure questionnaire; CI = confidence interval; ED = emergency department; ERAS = enhanced recovery after surgery; GP = general practice; HAH = hospital at home; HbA1c = glycated hemoglobin A1c; HF = heart failure; HR = hazard ratio; LDL = low density lipoprotein; LOS = length of stay; NR = not reported; PCMH = patient-centered medical home; QOL = quality of life; RCT = randomized controlled trial; RM = remote monitoring; ROB = risk of bias; RR = relative risk; STS = structured telephone support; STS HM = structured telephone support human to machine interface; TFU = telephone follow-up; TM = telemonitoring; Tx = treatment; UC = usual care; vs = versus

Table 5 Studies of Care Transition Interventions Conducted in VA Settings

Study Design and setting (N) Years of observation | Patient population | Intervention | Summary of findings
Ho, 2007^63^ Retrospective cohort study using data from all VAMCs (N=4933) 2003-2004 | Acute coronary syndromes including acute MI and unstable angina | Inpatient and follow-up cardiology care | Compared with other levels of cardiology care (inpatient only, outpatient only, and neither inpatient nor outpatient), unadjusted all-cause mortality was lower for patients with inpatient and follow-up cardiology care (18.8% vs 22.1%, p = 0.009). In multivariable analysis adjusting for age, race, site, comorbidities, hospital presentation factors (TIMI risk score for STEMI or NSTEMI, left ventricular systolic dysfunction, abnormal serum creatinine level), receipt of PCI and/or CABG surgery, discharge medications, and follow-up visit with a primary care provider within 60 days after discharge, patients with inpatient and follow-up cardiology care remained at lower risk for mortality (HR 0.73, 95% CI 0.62-0.87).
Oddone, 1999^64^ Multi-site RCT 9 VAMCs (N=443) Observation period NR | CHF | Enhanced access to primary care | Enhanced access to primary care did not improve quality of life and increased hospital readmissions, with an average of 1.5 ±2.0 readmissions per 6 months of follow-up for patients who had enhanced access compared with 1.1 ±1.8 for those who received UC (P= 0.02).
Wakefield, 2008^65^ Single site RCT (N=148) 2002-2006 | CHF | Home telehealth | Readmission at 12 months comparing telephone and videophone groups combined vs control: 59% vs 41%; unadjusted OR 0.49 (95% CI 0.24-0.98; p = 0.04) Risk of all-cause admission was significantly lower in the intervention group, adjusted for age, mean LVEF, NYHA classification, and MLHF instrument proportional hazards model: HR 0.54 (95% CI 0.33-0.90; p = 0.02) Mortality did not differ between intervention and control at 3 or 12 months. A Cox proportional hazards model adjusting for age, mean LVEF, NYHA classification, and MLHF found no difference in mortality at 12 months (HR = 1.04; 95% CI: 0.49, 2.24; p = 0.91).
Fan, 2012^66^ Multisite RCT 20 VA hospital-based outpatient clinics (N=426) 2007-2009 | COPD | Comprehensive care management | Trial was stopped early due to excess risk of death in the intervention group (compared with UC; 17 vs 7%, p = 0.003) At that time, the 1-year cumulative incidence of COPD related hospitalization was 27% in the intervention group and 24% in the UC group (HR, 1.13 [95% CI, 0.70 to 1.80]; P = 0.62). An extensive evaluation by the study authors failed to identify a reason that mortality was higher in the intervention group.24
Fitzgerald, 1994^67^ Single-site RCT (N=668) 1988-1990 | General medicine/unselected | Telephone-based follow-up by nurse case managers | No significant differences between intervention and control groups in non-elective readmissions, readmission days, or total readmissions. No significant difference in mortality, Tx vs comparator (%): 10.5 vs 10.4, (p=0.90) Average follow-up, Tx vs comparator (months): 12.14 vs 12.23
Evans, 1993^68^ Single-site RCT (N=835) Observation dates NR | High-risk patients (risk-screening index score^*^ >=3) | Discharge planning | Patients receiving early discharge planning were more likely to return home after hospitalization and less likely to be readmitted within 9 months. Tx vs control, % of patients: 30-day readmission: 24 vs 35 (p=0.001) 9-month readmission: 55 vs 61 (p=0.08) Discharged to home: 79 vs 73 Discharged to nursing home: 15 vs 22 (p=0.05 for discharge location) Deceased at discharge: 2 vs 2 (p=NS) Deceased at 9 months: 16 vs 16 (p=NS) At home at 9 months: 62 vs 54 In nursing home at 9 months: 19 vs 26 (p=0.05 for location at 9 months)
Kasprow, 2007^69^ Multi-site implementation study with historical controls 8 VAMCs (N=484) 2001-2004 | Homeless Veterans hospitalized for mental illness | Critical time intervention community case management with structured needs assessment | Compared with historical controls, the intervention cohort:; - Had significantly fewer psychiatric problems at 3-, 6-, and 9-month follow-up (p<.001, p<.001, and p=.005, respectively).; - Spent significantly fewer days in institutional settings at the 6-, 9-, and 12-month follow-up intervals (p=.01, p=.001, and p=.001, respectively) compared with historical controls.; - Had significantly more days housed at 6-, 9-, and 12-month follow-up (p=.02, p=.001, and p=.001, respectively).; - Had significantly lower alcohol use than historical controls at 3-, 6-, and 9 month follow-up (p<.001, p<.001, and p=.001, respectively).; - Had significantly lower drug use at 3-, 6-, and 6-month follow-up (p<.001, p<.001, and p=.04, respectively).
Weinberger, 1996^31^ Multi-site RCT 9 VAMCs (N=1396) 1992-1994 | Inpatients with DM, COPD, or CHF | Discharge planning | In an intensive primary care intervention involving close follow-up by a nurse and PCP from pre-discharge to 6 months post-discharge, the proportion of patients readmitted within 6 months did not significantly differ between intervention and control patients: 49% vs 44% (p=0.06)
Cummings, 1990^70^ Single-site RCT (N=419) 1984-1987 | Severely disabled or terminally ill patients | HBHC | Total VA hospital days did not significantly differ between HBHC and control groups. HBHC patients spent a greater proportion of their hospital stay on the intermediate care ward (3.0 days vs 1.5 days) p<.03) and less time on general care wards (8.5 days vs 12.2 days, p<.04) than control group patients. Total per-patient hospital costs were lower in the HBHC group vs controls ($3000.24 vs $4245.84, p=0.03). HBHC patients had greater satisfaction with care (0.1 on a 3-point scale, p<.001) than controls, at 1 month. No significant group differences in satisfaction at 6 months. No significant differences in patient morale at either 1 or 6 months.

* Evans RL, Hendricks RD, Lawrence KV, Bishop DS. Factors influencing use of health care resources: A hospital-based risk screening index. Soc Sci Med. 1988;27(9):947. [pmid: 3227391]. .

Abbreviations: CABG = coronary artery bypass graft; CHF = congestive heart failure; CI = confidence interval; COPD = chronic obstructive pulmonary disease; DM = diabetes mellitus; HR = hazard ratio; HBHC = hospital-based home care; LVEF = left ventricular ejection fraction; MI = myocardial infarction; MLHF = Minnesota Living with Heart Failure; N = population/sample size; NR = not reported; NSTEMI = non-ST-segment elevation myocardial infarction; NYHA = New York Heart Association; OR = odds ratio; PCI = percutaneous coronary intervention; PCP = primary care provider; RCT = randomized controlled trial; STEMI = ST-segment elevation myocardial infarction; TIMI = Thrombolysis in Myocardial Infarction; UC = usual care; VA = Veterans Affairs; VAMCs = Veterans Affairs Medical Centers