# SUMMARY AND DISCUSSION

Health plan-sponsored fitness center memberships have the potential to reach many Americans and may be an effective strategy to increase physical activity and its associated health benefits. Surprisingly few studies assessed the impact of health plan-sponsored fitness membership benefits—we identified only one main study and three companion articles that assessed the impact of such benefits. Overall, the data are insufficient to grade the strength of the evidence for health plan-sponsored access to fitness centers through member benefits.

The four included articles provided limited data on rates of physical activity (KQ 1a) and health care costs and utilization (KQ 1c). There were no data on physical health outcomes of interest (i.e., weight, pain, glucose, blood pressure, health related quality of life) (KQ 1b) and none on satisfaction with health plans or retention of plan members (KQ 2). No studies assessed whether effects of health plan benefits varied by characteristics of the participants (KQ 3). Further, only one type of plan was assessed in all analyses; thus, no included studies assessed whether effects of health plan-sponsored fitness center memberships varied by benefit type (KQ 3). Data were of limited applicability; all analyses were conducted exclusively in patients 65 years of age and older and were from one geographic location in the United States.

## SUMMARY OF EVIDENCE

None of the included articles assessed physical activity as a primary outcome; the only metric of physical activity provided was descriptive information on frequency of fitness center visits. Overall, health plan members who opted to participate in the health plan-sponsored fitness center memberships made few visits to facilities. In the main study,22 members averaged 1.44 visits per week in Year 1 and 1.06 visits per week in Year 2. These averages were similar to those reported in a subset of members with diabetes.25 Additional analyses suggest that distance from fitness centers and history of depression influence the uptake of health plan-sponsored fitness center memberships. Enrollment in a fitness center and frequency of use are both associated with distance from gyms.23 While history of depression is not associated with participation in a fitness center benefit, health plan members with a history of depression made fewer visits and were at greater risk of lapses in their participation compared with nondepressed members.24

We found some limited evidence to support the effects of health plan-sponsored fitness center memberships on health care costs and utilization. While participants in the Silver Sneakers program made more primary and specialty care visits, overall health care costs were significantly lower.22 These saving were likely due to fewer inpatient admissions. Similar patterns of health care use and costs were seen among health plan members with diabetes.25

## IMPLICATION OF FINDINGS

The clearest finding of this evidence synthesis is that the existing knowledge base does not provide enough data to make evidence-driven policy recommendations about the health and economic effects of health plan-sponsored fitness center membership benefits. The limited evidence available suggests that, if offered, health plan members will use fitness center memberships. However, internal and external barriers to optimal rates of use of such benefits remain.

Overall, health plan members who opted into the Silver Sneakers program tended to have fewer chronic illnesses. These findings complement a recent study that found health plans offering coverage for fitness center memberships attract and retain enrollees with better self-reported health.27 Together, these finding suggest that adding fitness center memberships to health plan benefits facilitates favorable selection of healthier enrollees, which in turn may lower health care costs by adding and retaining less costly individuals to the risk pool. However, health systems such as the VA have a higher proportion of individuals with chronic diseases (e.g., obesity, diabetes, arthritis). If the VA is able to engage these populations to use fitness center memberships, the cost savings could be significant, particularly for Veterans whose average weekly attendance is more than 1 visit.22 The results of the study by Nguyen et al.25 suggest that there may be an earlier and greater return on investment for populations who are at higher risk. Specifically, diabetic participants in the Silver Sneakers program had greater reductions in total health care expenditures than the general population of participants analyzed in Nguyen et al. (-$1230 vs. $500).22,25

Other findings suggest that a participant's distance from the fitness center also plays a role in benefit uptake and, after enrollment, frequency of use.23 Thus, health insurers who have a large proportion of rural enrollees who travel greater distances to fitness centers may have lower uptake of these benefits. Such health insurers may want to structure fitness center benefits that pay per visit instead of per membership or that automatically discontinue monthly fitness center memberships following lapses in use. This has implications for the VA patient population. Many Veterans travel long distances to access VA facilities. Thus, the VA would have to engage local and community-based facilities (e.g., commercial) closer to Veterans' homes in order to optimize benefit uptake and frequency of use. Also, health plans that have older enrollees with more physical limitations due to chronic health conditions may choose to selectively coordinate with fitness centers that offer appropriate exercise options (e.g., pool-based activities, low-impact aerobics classes). Despite these issues, evidence suggest that health plan members who elect to join fitness center programs incurred lower overall health care costs, even among members with chronic illnesses.22,25 Health insurers evaluating whether to implement such programs should look for ways to enhance more frequent use of fitness centers over time, such as an attendance requirement for continued access, in the design structure of the benefit.

## STRENGTHS AND LIMITATIONS

Our study has a number of strengths, including a protocol-driven review, a comprehensive search, and careful quality assessment. We also allowed inclusion of a wide array of observational and experimental studies and sought to collect both patient-level outcomes (e.g., physical activity levels, biophysical markers) and system-level outcomes (e.g., health care costs, health plan member retention rates). However, limitations to our evidence review exist. The greatest limitation of this review is the lack of relevant studies—and particularly no data relevant to KQ 2 and KQ 3. We limited our search to English-language articles and only included citations from North America, Western Europe, Australia, and New Zealand. We maintained this search limitation because we lacked translation resources and, more importantly, wanted to prioritize studies that were applicable to the U.S. medical system and populations, specifically Veterans. It was the opinion of the investigators and our stakeholders that the resources needed to translate non-English articles had a low potential likelihood of identifying relevant data. To the extent that studies applicable to the United States were published in languages other than English or were conducted outside these countries, we may have failed to include relevant studies. Also, the single included study and its associated companion articles all used retrospective observational designs, which has important implications for the strength of associations explored in these studies. Some key limitations were the limited ability to control for residual confounding due to nonrandomized design, no measure of overall physical activity outside of fitness center visits, and no data on the type and quality of physical activity conducted during fitness center visits. In addition, it is crucial to assess fitness center membership prior to and separate from the rollout of fitness center benefits in order to assess whether the benefit is reaching new or lapsed gym users or supplanting memberships of existing fitness center users. In other words—is the benefit enhancing access for people who are not physically active without the benefit but who would become physically active with the benefit? One strength of the included studies, however, was their use of existing “real world” administrative and claims data.

## RECOMMENDATIONS FOR FUTURE RESEARCH

Offering partial or full gym membership discounts is a common practice. For example, according to the Employer Health Benefits 2012 Annual Survey from the Kaiser Family Foundation and Health Research and Educational Trust,28 65 percent of all large firms (i.e., 200 or more workers) offer gym membership discounts or onsite exercise facilities—highlighting the need for evaluation and identification of best practices related to this increasingly offered benefit. However, results of our review confirm that the current body of literature is weak and insufficient to identify whether these programs improve outcomes and, if so, what are the best practices associated with implementing them. Thus, additional studies are needed to assess the potential merits, costs, and challenges of health plan-sponsored fitness center benefits in order to better inform VA policy. We used the framework recommended Robinson et al.29 to identify gaps in evidence and classify why these gaps exist (Table 3).

Table 3 Evidence gaps and future research

Evidence Gap | Reason | Type of Studies to Consider
Patients
Absence of data for patients other than those ≥ age 65 | Insufficient information | - Multisite cluster RCTs; - Quasi-experimental studies; - Prospective cohort studies
Interventions
Silver Sneakers program was the only benefit assessed | Insufficient information | - RCTs of head-to-head comparisons of different types of benefit structures; - Quasi-experimental studies comparing different types of policy changes that impact benefit structures
Outcomes
Uncertain effects on:; - Physical activity levels; - Physical health outcomes; - Health care costs and utilization | Insufficient information | - Multisite cluster RCTs; - Prospective cohort studies; - Nonrandomized trials (pre-post designs); - Nonrandomized controlled before-and-after studies
Uncertain effects on health plan member:; - Satisfaction; - Retention | Insufficient information | - Multisite cluster RCTs; - Prospective or retrospective cohort studies; - Nonrandomized controlled before-and-after studies; - Qualitative studies

Abbreviation: RCT = randomized controlled trial

### Potential Study Designs for Future Research

Existing studies lack diversity in included populations, benefits assessed, outcomes collected, and study designs employed. There are numerous possibilities regarding future research in this area. In particular, a variety of study designs can be employed—each having their own strengths and weaknesses. Three broad types of possible study designs and specific examples are introduced in Table 4, including (1) experimental (e.g., cluster randomized controlled trial), (2) quasi-experimental (e.g., interrupted time series design), and (3) observational (e.g., prospective cohort study, retrospective cohort study using administrative data).

Table 4 Comparisons of study designs used to assess effects of health plan-sponsored fitness benefits

Study Designs | Major Strengths | Major Limitations
Cluster randomized controlled trial | - Randomization to treatment (i.e., the fitness benefit) or control minimizes the influence of unaccounted, unmeasured factors (i.e., confounding variables) and reduces selection bias.; - Substantial control exists over measurement, such as included measures, as well as length of followup and timing.; - There is greater strength of evidence and confidence in results/causality.; - There is the greatest level of control over structure of the intervention (i.e., benefit).; - There is the possibility of comparing different benefit structures using multiple active comparators (i.e., comparative effectiveness trials). | - Threats to validity are still possible if randomization is not successful; results also may be undermined if significant and/or differential dropouts occur.; - Design is potentially time-consuming, with a longer lag time in generating findings compared to retrospective cohort studies using existing administrative data.; - Design has potentially higher costs than retrospective cohort studies using existing administrative data.; - External validity/generalizability is potentially limited if there is a highly selected population, setting, and tightly controlled implementation with resources/staff not available in “real world” settings.; - Design may pose a measurement burden for participants.
Interrupted time series design | - This design allows assessment of temporal trends in variables of interest before and after the event (i.e., policy change to include fitness center memberships).; - There is potentially lower cost than RCTs and prospective designs if using existing data sources. | - This design has a lack of control over unaccounted, unmeasured factors (i.e., confounding variables).; - Design is potentially less feasible; it would need to identify an event and have access to relevant data before and after a policy change.; - Design may require a large sample size.; - There is no control over structure of benefit unless policymakers consult with researcher.
Prospective cohort study | - Substantial control exists over measurement, such as measure diversity (number and type), as well as length of followup and timing.; - There is greater “real-world” applicability compared to tightly controlled randomized trials.; - There is greater strength of evidence than with other observational designs such as case-control and retrospective cohort designs because the sequence of event can be assessed. | - Time and cost investment is likely substantial because of the need for a large sample size and multiple assessments.; - There is a significant measurement burden for participants.; - This design is potentially less feasible and must identify the setting prior to benefit and enrollment, which may pose a significant logistical barrier.; - There is a greater risk of bias, lower quality, and lower strength of evidence compared to RCTs.; - There is no control over the structure of benefit.
Retrospective cohort study using administrative data | - This design is convenient if datasets are available and accessible (e.g., claims data).; - Time and costs required are potentially less than other designs.; - This design uses a similar method to existing studies, making it possible to confirm/replicate prior findings. | - Design is limited by the information available and existing variables (e.g., type, quality, timing, followup).; - Relevant data must be available and affordable; a large sample size is necessary to create a cohort of interest and define an adequate control group.; - Compared to other designs, risk of bias is highest and quality and strength of evidence are lowest.; - There is no control over the structure of benefit.

Abbreviation: RCT = randomized controlled trial

A cluster randomized controlled trial is a form of randomized controlled trial where groups of subjects or sites (e.g., VA medical centers) are the unit of randomization to treatment or control rather than individual participants. An interrupted time series design involves multiple measurements prior to and following an event (e.g., policy change to add fitness center membership benefits), which allows for evaluation of temporal trends but does not include randomization to study conditions. In an observational prospective cohort study, a defined group of individuals is followed over time before outcomes and exposures are measured. Retrospective cohort studies examine past exposures and outcomes. Table 4 gives an overview of the major strengths and limitations of these selected study design alternatives tailored to future research on health plan-sponsored fitness center memberships. We considered a variety of domains such as level of control over benefit structure, measurement/assessment, internal validity, generalizability, and feasibility (e.g., time, cost).

When weighing which study designs to use, researchers should always start with what is the best design to answer the research question at hand. However, researchers must also carefully weigh the tradeoffs in costs, feasibility, time, quality of evidence, and generalizability, which differ among the various study design options. Previous research on health plan-sponsored access to fitness memberships has exclusively used retrospective observational designs. Compared with prospective or experimental designs, retrospective observational designs allow for rapid generation of findings if existing data can be used. However, they offer the lowest strength of evidence when compared with the other designs described above and do not allow for control over the benefit structure. Moreover, retrospective observational designs may offer only limited information on complex behaviors like physical activity. The existing literature is limited in this regard and only provides descriptive information on the number of gym visits. Future studies should assess the quality of the physical activity (e.g., moderate vs. vigorous) and the time spent engaging in the activity.

Prospective cohort and quasi-experimental designs, such as interrupted time series designs, provide greater strength of evidence through establishing temporality of events compared with retrospective designs, as well as offering control over the type and quality of measures collected. These designs also come at higher costs, are more time consuming, may pose significant measurement burden on participants, and are impractical for rare events such as shifts in policies. In addition, these designs do not allow for control over the structure of the benefits. Also for interrupted time series designs, it can be difficult to disentangle the effects of the benefit from natural temporal trends without establishing a contemporaneous control group, and use of existing datasets may limit the quality and type of variables assessed.

When assessing the impact of providing memberships to fitness centers through health plan-sponsored benefits, RCTs offer the greatest strength of evidence. These designs also allow for control over the intervention tested (i.e., the benefit structure). Moreover, randomized designs can allow for direct comparisons of different benefit structures through comparative effectiveness trials (head-to-head comparisons). Also, RCTs can allow testing of different incentive strategies (e.g., cash rewards, premium discounts, loss of benefit based on attendance) to encourage continued use of fitness centers. Measurement of complex outcomes like physical activity can be built into the design of trials through the use of objective and automatic physical activity monitoring (e.g., pedometers with wireless data upload). However, randomized trials also tend to be costly and time consuming. In addition, the evidence generated may have limited generalizability if the study was conducted in a tightly controlled research environment with highly selected populations. Efficiencies can be built into theses design such as using cluster randomized designs and using existing data sources such as VA electronic medical records.

## CONCLUSIONS

Health plan-sponsored fitness center memberships have the potential to increase levels of physical activity and, subsequently, improve health and economic outcomes for Veterans. However, few studies have assessed the impact of health plan-sponsored fitness membership benefits. The evidence base for these claims remains weak due to study design limitations, and insufficient due to the paucity of literature. The limited evidence provides support for reductions in health care costs and utilization when comparing health plan members who choose to participate in health plan-sponsored gym memberships with those who do not—but these results may not be generalizable to Veterans and are based on study designs that could be subject to bias. The existing literature provides little insight into other outcomes such as physical activity, physical health outcomes, or health plan member satisfaction or retention. Thus, further evidence is needed on which to base policy recommendations on the merits of providing health plan-sponsored fitness center memberships.