# REFERENCES

1 Bauman AE. Updating the evidence that physical activity is good for health: an epidemiological review 2000-2003. J Sci Med Sport. 2004;7(1 Suppl):6-19. [pmid: 15214597].
2 Vogel T, Brechat PH, Lepretre PM, et al. Health benefits of physical activity in older patients: a review. Int J Clin Pract. 2009;63(2):303-20. [pmid: 19196369].
3 Tseng CN, Gau BS, Lou MF. The effectiveness of exercise on improving cognitive function in older people: a systematic review. J Nurs Res. 2011;19(2):119-31. [pmid: 21586989].
4 Bize R, Johnson JA, Plotnikoff RC. Physical activity level and health-related quality of life in the general adult population: a systematic review. Prev Med. 2007;45(6):401-15. [pmid: 17707498].
5 Glenister D. Exercise and mental health: a review. J R Soc Health. 1996;116(1):7-13. [pmid: 8683544].
6 Gerber M, Puhse U. Review article: do exercise and fitness protect against stress-induced health complaints? A review of the literature. Scand J Public Health. 2009;37(8):801-19. [pmid: 19828772].
7 Penedo FJ, Dahn JR. Exercise and well-being: a review of mental and physical health benefits associated with physical activity. Curr Opin Psychiatry. 2005;18(2):189-93. [pmid: 16639173].
8 Bucksch J, Schlicht W. Health-enhancing physical activity and the preventionof chronic diseases--an epidemiological review. Soz Praventivmed. 2006;51(5):281-301. [pmid: 17176649].
9 Taylor AH, Cable NT, Faulkner G, et al. Physical activity and older adults: a review of health benefits and the effectiveness of interventions. J Sports Sci. 2004;22(8):703-25. [pmid: 15370483].
10 Franklin BA. Physical activity to combat chronic diseases and escalating health care costs: the unfilled prescription. Curr Sports Med Rep. 2008;7(3):122-5. [pmid: 18477867].
11 Colditz GA. Economic costs of obesity and inactivity. Med Sci Sports Exerc. 1999;31(11 Suppl):S663-7. [pmid: 10593542].
12 Department of Health and Human Services, Centers for Disease Control and Prevention. 2008. Physical Activity Guidelines for Americans. Available at: http://www.cdc.gov/physicalactivity/everyone/guidelines/adults.html. August 1, 2012.
13 Department of Health and Human Services, Centers for Disease Control and Prevention. 2007. U.S. Physical Activity Statistics. Available at: http://apps.nccd.cdc.gov/PASurveillance/StateSumResultV.asp?CI=&Year=2007&State=0#data. August 1, 2012.
14 Littman AJ, Forsberg CW, Koepsell TD. Physical activity in a national sample of veterans. Med Sci Sports Exerc. 2009;41(5):1006-13. [pmid: 19346987].
15 Cerin E, Leslie E, Sugiyama T, et al. Perceived barriers to leisure-time physical activity in adults: an ecological perspective. J Phys Act Health. 2010;7(4):451-9. [pmid: 20683086].
16 Salmon J, Owen N, Crawford D, et al. Physical activity and sedentary behavior: a population-based study of barriers, enjoyment, and preference. Health Psychol. 2003;22(2):178-88. [pmid: 12683738].
17 U.S. Census Bureau. Health Insurance Highlights. 2010. Available at: http://www.census.gov/hhes/www/hlthins/data/incpovhlth/2010/highlights.html. August 1, 2012.
18 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol. 2009;62(10):1006-12. [pmid: 19631508].
19 Wilczynski NL, McKibbon KA, Haynes RB. Response to Glanville et al.: How to identify randomized controlled trials in MEDLINE: ten years on. J Med Libr Assoc. 2007;95(2):117-8. author reply 119-20. [pmid: 17443240].
20 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/search-for-guides-reviewsand-reports/?pageaction=displayproduct&mp=1&productID=318. August 1, 2012.
21 Fody-Urias BM, Fillit H, Hill J. The effect of a fitness program on health status and health care consumption in Medicare MCOs. Manag Care Interface. 2001;14(9):58-64. [pmid: 11569307].
22 Nguyen HQ, Ackermann RT, Maciejewski M, et al. Managed-Medicare health club benefit and reduced health care costs among older adults. Prev Chronic Dis. 2008;5(1):A14. [pmid: 18082003].
23 Berke EM, Ackermann RT, Lin EH, et al. Distance as a barrier to using a fitness-program benefit for managed medicare enrollees. J Aging Phys Act. 2006;14(3):313-323. [pmid: 17090808].
24 Nguyen HQ, Koepsell T, Unutzer J, et al. Depression and use of a health plan-sponsored physical activity program by older adults. Am J Prev Med. 2008;35(2):111-7. [pmid: 18547781].
25 Nguyen HQ, Maciejewski ML, Gao S, et al. Health care use and costs associated with use of a health club membership benefit in older adults with diabetes. Diabetes Care. 2008;31(8):1562-7. [pmid: 18458143].
26 Putnam KG, Buist DS, Fishman P, et al. Chronic disease score as a predictor of hospitalization. Epidemiology. 2002;13(3):340-6. [pmid: 11964937].
27 Cooper AL, Trivedi AN. Fitness memberships and favorable selection in Medicare Advantage plans. N Engl J Med. 2012;366(2):150-7. [pmid: 22236225].
28 The Kaiser Family Foundation and Health Research Educational Trust. Employer Health Benefits 2012 Annual Survey. Available at: http://ehbs.kff.org/. September 27, 2012.
29 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm. May 22, 2012.