# METHODS

## TOPIC DEVELOPMENT

This review was commissioned by the VA Evidence-based Synthesis Program. The topic was nominated and key questions developed after a refinement process that included a preliminary review of published peer-reviewed literature and consultation with experts, investigators, and key stakeholders. The final key questions (KQs) were:

KQ 1. What are the effects of policy/benefits packages that include vouchers, rebates, premium reductions, or other economic incentives to encourage physical activity through fitness center memberships on:

a. Physical activity participation rates among plan members?
b. Health outcomes demonstrated to be improved by physical activity (i.e., weight, pain, glucose, blood pressure, health-related quality of life)?
c. Overall health care costs and health care utilization?

KQ 2. What are the effects of policy/benefits packages that include vouchers, rebates, premium reductions, or other economic incentives to encourage physical activity through fitness center memberships on satisfaction with the health plan and retention of members in the health plan?

KQ 3. Do the effects of policy/benefits packages to encourage physical activity vary by specific characteristics of the package (premium vs. lump sum) or age, sex, and physical illness of participants?

## ANALYTIC FRAMEWORK

The standard protocol used for this review maps to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.18 Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic framework for assessing effects of health plan-sponsored fitness center benefits

## SEARCH STRATEGY

In consultation with a master librarian, we searched MEDLINE^®^ (via PubMed^®^), Embase^®^, and the Cochrane Database of Systematic Reviews for peer-reviewed publications comparing health plan-sponsored strategies to encourage physical activity through fitness center memberships with standard benefit plans from database inception through January 2012. We selected free-text terms to search titles and abstracts as well as validated search terms for both randomized controlled trials19 and relevant observational studies adapted from the Cochrane Effective Practice & Organization of Care Group search, version 1.9. We limited the search to articles published in the English language involving human subjects 18 years of age and older. The full search strategy is provided in Appendix A. An updated search for publications was conducted in May 2012. We also evaluated the bibliographies of included primary studies. All citations were imported into an electronic database, EndNote^®^ Version X5 (Thomson Reuters, Philadelphia, PA) for referencing. As a mechanism to assess the risk of publication bias, we searched www.ClinicalTrials.gov for completed but unpublished studies in July 2012.

## STUDY SELECTION

Using prespecified inclusion and exclusion criteria, two reviewers assessed titles and abstracts for relevance to the KQs. Full-text articles identified by either reviewer as potentially relevant were retrieved for further review. Each article retrieved was examined by two other reviewers against the eligibility criteria. Disagreements on inclusion, exclusion, or major reason for exclusion were resolved by discussion or by a third reviewer. The criteria to screen articles for inclusion or exclusion at both the title-and-abstract and full-text screening stages is shown in Table 1. Studies excluded at the full-text review stage are listed with the reasons for exclusion in Appendix B.

Table 1 Summary of inclusion and exclusion criteria

Study characteristic | Inclusion criteria | Exclusion criteria
Population | Adults ≥18 years of age with or without a chronic illness | Studies with populations <18 years of age
Intervention | - Intervention or “exposure” must meet the following definition: Health plan-sponsored strategies (e.g., vouchers, rebates, premium reductions) to encourage physical activity through fitness center memberships; If the intervention includes a variety of fitness or exercise-related strategies in addition to facilitating gym memberships, the majority of activities (50% or more) should be like those typically provided through a gym to increase physical activity (e.g., yoga classes, walking clubs, trainer) | Study excluded if exposure meets any of the following criteria:; - Studies of health plan-sponsored access to rehabilitation facilities; - Studies of access to fitness centers not offered through health plan-sponsored economic incentives; - Worksite wellness programs; - Interventions that use a wide array of health promotion strategies not typically provided at a fitness center (e.g., health risk assessments, preventive health screenings) if the effects of fitness-related activities are not distinguishable from other components of the intervention
Comparator | - Standard benefits packages (health plans that do not offer strategies to encourage physical activity through fitness center memberships; - Head-to-head comparisons of different health plan-sponsored programs to encourage physical activity through fitness center memberships | None; study must have a control group
Outcome | KQs 1 and 3:; - Physical activity participation rates (e.g., minutes spent being physically active, visits to fitness center); - Weight control (i.e., weight loss or maintenance of current weight); - Pain level using validated measures; - Biophysical markers such as laboratory or physiological markers of glucose control or blood pressure; - Health-related quality of life; - Health care utilization of medical resources (e.g., in-patient admissions, emergency visits, primary care or specialty visits); - Health care costs (prioritizing total health care costs); KQ 2:; - Member satisfaction with health plan; - Retention of plan members | None
Timing | For longitudinal studies, outcomes must be measured at ≥6 months from start of assessment period | For longitudinal studies, outcomes reported <6 months from start of assessment period
Setting | - Study conducted in North America, Western Europe, Australia, New Zealand^a^; - Public or private health plans | Conducted in countries other than those specifically listed as included
Study design^b^ | - Original data; - Prospective and retrospective observational studies with comparator (sample size ≥100 subjects); - Patient or cluster randomized trials (all sample sizes); - Interrupted time-series designs that have ≥3 measurement points prior to and after the intervention is begun | Cross-sectional studies and other observational study designs not specifically listed as “included” study designs
Publications | - English-language only; - Peer-reviewed article | Non-English language publication

a Rationale is that medical systems in economically developed countries with sufficient similarities in the system and culture are applicable to U.S. medical care.

b Study designs recommended by the Cochrane Effective Practice and Organization of Care Group.

Abbreviation: KQ = Key Question

## DATA ABSTRACTION

We designed the data abstraction forms to collect the data required to evaluate the eligibility criteria for inclusion in this review, as well as population characteristics and other data needed for determining outcomes and risk of bias (Appendix C). We paid particular attention to the details of the intervention to assure that it was offered through a health insurance plan as a health benefit and that it was engaged in by the participant at a fitness center. We did not evaluate studies on workplace wellness or health plan access to rehabilitation facilities. One researcher abstracted the data, and a second reviewed the completed abstraction form alongside the original article to check for accuracy and completeness. As with full-text review, disagreements were resolved by discussion or by a third reviewer. We supplemented abstraction of published data by contacting authors for missing information. We contacted one author who replied with additional information about benefits structure and costs.

## QUALITY ASSESSMENT

Data necessary for assessing quality and applicability, as described in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews,20 also were abstracted. Per the AHRQ Methods Guide,20 threats to internal validity of systematic review conclusions based on observational studies were identified through assessment of the body of observational literature as a whole, with an examination of characteristics of individual studies. Study-specific issues that were considered include: potential for selection bias (i.e., degree of similarity between intervention and control patients); performance bias (i.e., differences in care provided to intervention and control patients not related to the study intervention); attribution and detection bias (i.e., whether outcomes were differentially detected between intervention and control groups); and magnitude of reported intervention effects (see the section on “Selecting Observational Studies for Comparing Medical Interventions” in the Methods Guide). Using these quality criteria, we assigned a summary quality score (good, fair, poor) to included studies.20 For each study, two investigators independently assigned a summary quality rating; disagreements were resolved by consensus or by a third investigator as before.

## DATA SYNTHESIS

We critically analyzed studies to compare their characteristics, methods, and findings to determine the feasibility of completing a quantitative synthesis (i.e., meta-analysis) based on the volume of relevant literature, the completeness of the results reported and the conceptual homogeneity of the studies. As quantitative synthesis was not possible, we analyzed the results qualitatively.

## RATING THE BODY OF EVIDENCE

In addition to rating the quality of individual studies, we evaluated the overall quality of the evidence for each KQ as described in the Methods Guide,20 if feasible. This approach requires assessment of four domains: risk of bias, consistency, directness, and precision. Additional domains considered were strength of association (magnitude of effect) and publication bias. These domains were considered qualitatively, and a summary rating of high, moderate, low, or insufficient strength of evidence was assigned after discussion by two reviewers.

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership. A transcript of their comments can be found in Appendix D, which elucidates how each comment was considered in the final report.