# PEER REVIEW COMMENTS

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | Yes. The scope is clear but the aims are worded as if the focus is on whether benefit packages that include incentives for fitness center use increase physical activity. Clearly the scope is broader than this, as evidenced by the conceptual model and the sub aims of key question #1. There are a multitude of health benefit designs that involve incentives. The goal is more generally to improve health, reduce costs, and to meet a market demand (i.e. a more common reason employer health executives report including incentives is that they are “part of the plan”; in other words, they can't get by designing a health benefit package any longer that leaves health and wellness benefits out of the package – there is a demand among purchasers). The review searched for effects beyond physical activity. I would recommend rewording the key questions to reflect the interest in whether benefits result in improved health when they include incentives to use a fitness facility. This frames the focus on broader metrics of improved health but still defines the focus on fitness facilities, as opposed to the multitude of other health/wellness programs and incentives in the marketplace today. I have to keep reminding myself that the focus is really very specifically on incentives to encourage fitness center use. The “effects” are broader than physical activity (e.g. participation, downstream effects of PA, and cost/utilization). Consider: What are the effects of policy/ benefits packages that include vouchers, rebates, premium reductions, or other economic incentives to improve health specifically through encouraging the use of fitness centers. | Thank you. We agree that the scope is beyond physical activity. The Key Questions, however, were created in collaboration with, and approved by, the technical expert partners and stakeholders. Therefore, we cannot modify them at this time for the report.
2 | Yes, and no comments from reviewer 2. | Thank you.
3 | Yes, and no comments from reviewer 3. | Thank you.
4 | Yes. Clear delineation of purpose and KQs, scope is defined with clear inclusion criteria and exclusion criteria, and the methods follow clearly outlined systematic review processes. | Thank you.
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | No. I do think that there are likely a large number of “program evaluations” that have been conducted by employers or health plans to ascertain net costs of such a benefit. To the extent that these evaluations are absent from the literature, it likely implies that they were negative studies or of poor quality. | Thank you. We agree, and our focus was on peer-reviewed, published literature.
2 | No, and no comments from reviewer 2. | Thank you.
3 | No, and no comments from reviewer 3. | Thank you.
4 | No. Transparency in logic makes the results of the logic flow consistent with the findings presented | Thank you.
Question 3: Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No. I do not know of any. There was a study by Fody-Urias about 10 years ago that looked at SS, but I believe it was uncontrolled and likely of limited methodologic rigor. | Thank you. This study was excluded during citation screening but marked for background. Although this paper did look at Silver Sneakers, the study design was not one of interest because there was no control group.
2 | It would have been useful and relevant to look at or contrast the literature of employer sponsored programs to encourage PA through fitness center memberships. Whether an is employer sponsored vs healthplan sponsored seems like a trivial distinction in terms of potential outcomes and mechanism related to effectiveness. | Thank you. Employer-sponsored programs were not in the scope of the project. This project was focused on the VA context (i.e., health plan members as opposed to employees).
3 | No, and no comments from reviewer 3 | Thank you.
4 | No. The search was in-depth and appears to have included the correct type of studies. Personally, I am also not aware of any other research studies that have been reported in this area. | Thank you.
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | There are a few missed opportunities to frame the discussion for consumption by both the VA and the research community. I have highlighted three of these in comment boxes on the draft. There is also a fourth, related to behavioral economics, which is also discussed below. First, the authors should review and reference the Kaiser Family Foundation annual employer survey. In the most recent year, the survey captured the current practices of >2000 employers regarding the goals and design of health wellness programs and incentives included in health benefit design. Clearly, the train has left the station. To the extent that there may be ‘better practices’ and resources for some benefit designs may constitute waste, these programs demand greater evaluation. | Thank you. We have added information related to the Kaiser Family Foundation and Health Research and Educational Trust Employer Health Benefits 2012 Annual Survey in the discussion section.
1 | Second, the issue of distance as a moderator of the effect of fitness center incentives and use should be expanded more and tailored more for the VA. Specifically, give consideration to the challenges of VA facility-based health promotion programs in the context of large VISN areas. Consider the role of “local” programs that are provided closer to a Veteran's home, or at another Veteran service organization that is closer to them. These still need evaluation but could frame new research questions for VA investigators. | Thank you. We expanded on the issue of distance as relates to VA in the discussion section.
1 | Third, the discussion of alternative study designs is very good but also general. Consider giving an example of a randomized encouragement trial that blends to generalizability of a pragmatic, whole-population evaluation with the internal validity of randomization. See my comment on the draft. Last, I would recommend a slightly deeper discussion of the need for evaluating both the fitness resource as well as the nature of how fitness center use is encouraged. Behavioral econ studies have shown to some extent that you get what you pay for. In other words, if the incentive is for participation, there is greater participation but not necessarily improved health behavior or outcomes. The nature and direction of the incentive is a critical point of study in the future evaluation of these benefits. | Thank you. We elaborated on the role of incentives and encouragement in the discussion section.
1 | There is a missed opportunity here to underscore the enormity of the issue. The horse is out of the barn and we know very little about the health or economic impacts of these forms of incentives, which could divert limited resources from other areas of employee compensation (e.g. salary, other health benefits, lower premiums). Please see the annual Kaiser Family Foundation Employer Survey. The most recent findings are summarized on the kff website and could help to frame the magnitude of efforts to provide such incentives in the commercial sector. | Thank you. See response to related comments above.
1 | Cash rewards are currently the most common form of incentive used in the large employer sector to encourage wellness program use. It might be listed here separately from “other economic incentives” (under “Intervention”) for this purpose.; - add blood lipid control and improved work productivity (reduced absenteeism and presenteeism) to possible intermediate outcomes?; - add Non-medical cost reductions to Final Outcomes (again economic impact of work productivity, absence, disability, death, and replacement)? | Thank you. We understand these comments are regarding the framework presented. Figure 1 represents an analytic rather than conceptual framework. As such, the analytic framework is not intended to be a comprehensive representation of all outcomes.
1 | There is another opportunity here to relate this to the VA. Because many Veterans travel great distances to access VA facilities, a model that provides or encourages access to peripheral fitness facilities or programs (commercial or through CBOCs or other veteran-accessible organizations such as a VFW) could, in fact, have advantages. This may raise the relevance of encouraging greater research in this area as it may help specifically to serve unique needs of veteran patients. | Thank you. We added details on travel distance for Veterans to the discussion section.
1 | Might discuss briefly CRET designs. Specifically, pragmatic trials that randomize at the employer level to encouragement versus no encouragement of eligible employees to participate in a physical fitness benefit program. Treatment effects are estimated using an instrumental variables approach that uses random assignment as the instrument. This allows simultaneous assessment of both the encouragement step (interventions may include cash rewards, premium discounts, etc) and use of the fitness facility itself. | Thank you. We added information on the use of incentives as a strategy to increase compliance with the fitness center benefit to the Discussion section.
2 | Given that only one cohort of patients was found I agree it is very hard to make any generalizable statements regarding KQ1. | Thank you.
2 | In consideration of this proposed benefit the key piece of information is how likely people who are not likely to be regularly physically active without the benefit will convert to being physically active with the benefit. If people are already going to fitness clubs, addition of the benefit will not be beneficial. Similar the large number of people with no interest in attending fitness clubs lowers the of health improvement to a population who is offered the benefit change. I understand this is out of scope of this review but does highlight the relevant questions for population health improvement. | Thank you. We agree these are important points to consider, which are further elaborated and addressed in the Discussion section.
3 | I believe it would be helpful to look at Health Service Research Centers associated with health plans and review HEDIS measures of plans that offer gym membership for member utilization and satisfaction, and to see if a retrospective study could be possible using a common methodology across plans for behavioral and health outcomes. Niko Pronk of Health Partners would be a good place to start. | Thank you. This is an excellent idea for future study and one of the study designs addressed in the Recommendations for Future Research.
4 | On p. 6, in the Conclusion section, the end of the second sentence indicates the evidence remains “weak”. I would recommend changes this statement somewhat to read “…remains insufficient and weak, mostly due to study design limitations and small number of studies that meet criteria for inclusion.” On p. 8, second paragraph, line 9: I would recommend to insert “full or partial” between the words “providing” and “membership” | Thank you. These changes were incorporated.
Optional Dissemination and Implementation Questions
Question 5: Are there any clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | I believe VA National Center for Health Promotion at Durham VA is exploring linkages to outside facilities as a potential means to expand the reach or impact of the MOVE program. Perhaps this is what instigated this particular review in the first place. The review team should be aware of this, but it is worth mentioning. | Thank you.
2 | No comment from reviewer 2. | Thank you.
3 | No comment from reviewer 3. | Thank you.
4 | Unsure as I am not too familiar with the VA programs | Thank you.
Question 6: Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | Please see my comments under #4 above, as I believe these also have relevance to implementation needs. However, it is clear that the most direct interpretation of the review is that we currently know very little about the costs and effectiveness of health benefit designs that attempt to improve health through external facility use. The immediate need for implementation seems to be the design of natural experiments that help address this knowledge gap, both within and outside the VA. The review should clearly be framed for the VA research community (and I think it is already) and also designed to engage those investigators with program designers at local VAs or at the National Center. | Thank you. We agree, and the reviewer mentions some next likely steps.
2 | No comment from reviewer 2. | Thank you.
3 | To encourage future research among those with shared interests by speaking at meetings such as AHIP, YMCA-USA, and health plan health service researchers with health promotion interests. | Thank you. The ESP Coordinating Center dissemination plan includes some or all of the following as applicable: cyberseminar, email distribution, briefing to VA leaders, and manuscript publication.
4 | From the systematic review perspective, I don't think there is anything missing. To make the report more directly practical, it may be a good idea to add a series of interviews with health plans that have implemented this type of program to find out what additional analyses they may be using to justify the investment internally. Based on such findings, both a justification for doing this or not may be made as well as a more robust set of information to consider the actual program design elements that may make it a good value for the money. | Thank you. Interviews with health plans may be a direction for future research, but primary data collection is beyond the scope of this review.
Question 7: Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
1 | This should be made accessible to the purchasers (employers, Medicare, and state Medicaid administrators) who are either designing health benefits with public monies or are being asked to purchase such benefits from health plans. The purchasers are looking for answers but are also creating a market demand for these programs with little to know information about whether they work, or how to improve them to work best. This creates waste and could be directing limited resources away from other programs that have greater value for the dollar. Commercial health plans may not be concerned because they are profiting already; why support an evaluation that could show something profitable isn't working? Because of the limited scope and limited information to guide policy changes within the review, this review may be difficult to publish in a scientific journal. However, I would encourage the team try to do this and that distribution to CMMI and to the National Business Group on Health be considered strongly. | Thank you. The ESP Coordinating Center dissemination plan includes some or all of the following as applicable: cyberseminar, email distribution, briefing to VA leaders, and manuscript publication.
2 | No comment from reviewer 2. | Thank you.
3 | No comment from reviewer 3. | Thank you.
4 | I think this report would be of interest to AHIP (America's Health Insurance Plans) and ACHP (the Alliance of Community Health Plans) | Thank you. The ESP Coordinating Center dissemination plan includes some or all of the following as applicable: cyberseminar, email distribution, briefing to VA leaders, and manuscript publication.