# DATA ABSTRACTION ELEMENTS

Study Characteristics:

- Study design
- Study dates
- Study setting
- Geographical location
- Funding source
- Subject selection/enrollment in study
- Source of comparator population and comparator strategy
- Patient eligibility criteria for study matching characteristics

Population Characteristics:

- Number of subjects
- Gender
- Race
- Age
- Education
- Baseline physical activity level
- Smoking status
- Weight
- HbA1c (%)
- Lipids (total cholesterol, LDL, HDL)
- Blood pressure (systolic, diastolic)
- Other relevant comorbid conditions and baseline characteristics (e.g., comorbidities, preventive services index, health care use, health care costs, distance to fitness facility, income)

Intervention Components:

- Components of benefit
- Structure of benefit (e.g., vouchers, rebates, premium reductions)
- Payment structure
- Type of fitness centers available through benefit

Outcome Components:

- Physical activity participation rates
- Weight control
- Pain level using validated measures
- Biophysical markers
  ○ Glucose control
  ○ Blood pressure control
- Health-related quality of life
- Health care utilization of medical resources
- Health care costs
- Patient satisfaction with health plan
- Retention of plan members