# EXCLUDED STUDIES

All articles listed below were reviewed in their full-text version and excluded for the reason indicated. An alphabetical reference list follows the table.

Excluded studies with reasons

Reference | Not full publication, peer-reviewed, or primary data | Not English language | Not geographic location of interest | Not intervention of interest | Not study design of interest | Not outcome of interest
Abildso, 2010 | | | | | X
Ackermann, 2003 | | | | X
Ackermann, 2008 | | | | X
Anderson, 2001 | X
Anonymous, 2008 | X
Arlton, 1986 | X
Atherly, 2011 | | | | X
Bartlett-Prescott, 2005 | | | | X
Bertera, 1990 | X
Breuleux, 1993 | | | | X
Burnes, 1995 | X
Compton, 2006 | | | | X
Cooper, 2012 | | | | | | X
Cox, 1981 | | | | X
Deitz, 2005 | | | | X
Fielding, 1982 | X
Foote, 2006 | X
Gillman, 2001 | | | | X
Goetzel, 2001 | X
Goetzel, 1998 | | | | X
Haltiwanger, 2007 | X
Hochart, 2011 | | | | X
Kulesher, 2005 | X
Lambert, 2009 | | | X
Mayer, 2010 | | | | X
Nguyen, 2007 | | | | X
Orme-Johnson, 1997 | | | | X
Ozminkowski, 2001 | X
Ozminkowski, 2006 | | | | X
Ozminkowski, 2002 | | | | X
Patel, 2011 | | | X
Patel, 2010 | | | X
Pelletier, 2005 | | | | X
Pronk, 2002 | | | | X
Serxner, 2001 | | | | X
Shephard, 1982 | | | | X
Shephard, 1983 | | | | X
Shephard, 1982 | | | | X
Spencer, 1996 | | | | X
Spilman, 1986 | | | | X
Stevens, 1998 | | | | X
Terry, 1991 | | | | X
Wylie-Rosett, 2001 | | | | X

Note: At the request of a peer reviewer, we reconsidered one reference21 that was initially excluded at the title/abstract level; however, we retained our original conclusion that the reference could not be included based on our inclusion/exclusion criteria.

## LIST OF EXCLUDED STUDIES

Agency for Healthcare Research and Quality Group. Abildso CG, Zizzi SJ, Reger-Nash B. Evaluating an insurance-sponsored weight management program with the RE-AIM Model, West Virginia, 2004-2008. Prev Chronic Dis. 2010;7(3):A46. [pmid: 20394685].
Ackermann RT, Cheadle A, Sandhu N, et al. Community exercise program use and changes in healthcare costs for older adults. Am J Prev Med. 2003;25(3):232-7. [pmid: 14507530].
Ackermann RT, Williams B, Nguyen HQ, et al. Healthcare cost differences with participation in a community-based group physical activity benefit for medicare managed care health plan members. J Am Geriatr Soc. 2008;56(8):1459-65. [pmid: 18637982].
Anderson DR, Serxner SA, Gold DB. Conceptual framework, critical questions, and practical challenges in conducting research on the financial impact of worksite health promotion. Am J Health Promot. 2001;15(5):281-8. [pmid: 11502010].
Anonymous. Active seniors decrease health costs: Silver Sneakers study shows significant benefits in year two. Dis Manag Advis. 2008;14(5):7-9. 1.
Arlton D. A paying health promotion clinic: combining client services and student learning. J Allied Health. 1986;15(1):3-10. [pmid: 3957779].
Atherly A, Thorpe KE. Analysis of the treatment effect of Healthways' Medicare Health Support Phase 1 Pilot on Medicare costs. Popul Health Manag. Suppl 1. 2011;14:S23-8. [pmid: 21323616].
Bartlett-Prescott JD, Klesges LM, Kritchevsky SB. Health promotion referrals in an urban clinic: removing financial barriers influences physician but not patient behavior. Am J Health Promot. 2005;19(5):376-82. [pmid: 15895541].
Bertera RL. The effects of workplace health promotion on absenteeism and employment costs in a large industrial population. Am J Public Health. 1990;80(9):1101-5. [pmid: 2382748].
Breuleux C, Heck SK, Hollenback J, et al. Preliminary comparison of medical care costs between fitness center members and nonmembers. Am J Health Promot. 1993;7(6):405-7. [pmid: 10146814].
Burnes H. Personal health improvement program. HMO Pract. 1995;9(2):59-60. [pmid: 10143153].
Compton MT, Weiss PS, Phillips VL, et al. Determinants of health plan membership among patients in routine U.S. psychiatric practice. Community Ment Health J. 2006;42(2):197-204. [pmid: 16408152].
Cooper AL, Trivedi AN. Fitness memberships and favorable selection in Medicare Advantage plans. N Engl J Med. 2012;366(2):150-7. [pmid: 22236225].
Cox M, Shephard RJ, Corey P. Influence of an employee fitness programme upon fitness, productivity and absenteeism. Ergonomics. 1981;24(10):795-806. [pmid: 7318813].
Deitz D, Cook R, Hersch R. Workplace health promotion and utilization of health services: follow-up data findings. J Behav Health Serv Res. 2005;32(3):306-19. [pmid: 16010186].
Fielding JE. Effectiveness of employee health improvement programs. J Occup Med. 1982;24(11):907-16. [pmid: 6816911].
Foote SM. Medicare health support: reinventing chronic care. Am Heart Hosp J. 2006;4(1):39-42. [pmid: 16470103].
Gillman MW, Pinto BM, Tennstedt S, et al. Relationships of physical activity with dietary behaviors among adults. Prev Med. 2001;32(3):295-301. [pmid: 11277687].
Goetzel RZ. The financial impact of health promotion and disease prevention programs--why is it so hard to prove value?. Am J Health Promot. 2001;15(5):277-80. [pmid: 11502009].
Goetzel RZ, Dunn RL, Ozminkowski RJ, et al. Differences between descriptive and multivariate estimates of the impact of Chevron Corporation's Health Quest Program on medical expenditures. J Occup Environ Med. 1998;40(6):538-45. [pmid: 9636934].
Haltiwanger R. Medicare health support program: better quality of life for chronically ill seniors. Tenn Med. 2007;100(7):33. [pmid: 17682697].
Hochart C, Lang M. Impact of a comprehensive worksite wellness program on health risk, utilization, and health care costs. Popul Health Manag. 2011;14(3):111-6. [pmid: 21241173].
Kulesher RR. Medicare-the development of publicly financed health insurance: Medicare's impact on the nation's health care system. Health Care Manag (Frederick). 2005;24(4):320-9. [pmid: 16284515].
Lambert EV, da Silva R, Fatti L, et al. Fitness-related activities and medical claims related to hospital admissions - South Africa, 2006. Prev Chronic Dis. 2009;6(4):A120. [pmid: 19754996].
Mayer C, Williams B, Wagner EH, et al. Health care costs and participation in a community-based health promotion program for older adults. Prev Chronic Dis. 2010;7(2):A38. [pmid: 20158966].
Nguyen HQ, Ackermann RT, Berke EM, et al. Impact of a managed-Medicare physical activity benefit on health care utilization and costs in older adults with diabetes. Diabetes Care. 2007;30(1):43-8. [pmid: 17192331].
Orme-Johnson DW, Herron RE. An innovative approach to reducing medical care utilization and expenditures. Am J Manag Care. 1997;3(1):135-44. [pmid: 10169245].
Ozminkowski RJ, Goetzel RZ. Getting closer to the truth: overcoming research challenges when estimating the financial impact of worksite health promotion programs. Am J Health Promot. 2001;15(5):289-95. [pmid: 11502011].
Ozminkowski RJ, Goetzel RZ, Wang F, et al. The savings gained from participation in health promotion programs for Medicare beneficiaries. J Occup Environ Med. 2006;48(11):1125-32. [pmid: 17099448].
Ozminkowski RJ, Ling D, Goetzel RZ, et al. Long-term impact of Johnson & Johnson's Health & Wellness Program on health care utilization and expenditures. J Occup Environ Med. 2002;44(1):21-9. [pmid: 11802462].
Patel D, Lambert EV, da Silva R, et al. Participation in fitness-related activities of an incentive-based health promotion program and hospital costs: a retrospective longitudinal study. Am J Health Promot. 2011;25(5):341-8. [pmid: 21534837].
Patel DN, Lambert EV, da Silva R, et al. The association between medical costs and participation in the vitality health promotion program among 948,974 members of a South African health insurance company. Am J Health Promot. 2010;24(3):199-204. [pmid: 20073387].
Pelletier KR. A review and analysis of the clinical and cost-effectiveness studies of comprehensive health promotion and disease management programs at the worksite: update VI 2000-2004. J Occup Environ Med. 2005;47(10):1051-8. [pmid: 16217246].
Pronk NP, Boucher JL, Gehling E, et al. A platform for population-based weight management: description of a health plan-based integrated systems approach. Am J Manag Care. 2002;8(10):847-57. [pmid: 12395953].
Serxner S, Gold D, Anderson D, et al. The impact of a worksite health promotion program on short-term disability usage. J Occup Environ Med. 2001;43(1):25-9. [pmid: 11201766].
Shephard RJ, Corey P, Renzland P, et al. The influence of an employee fitness and lifestyle modification program upon medical care costs. Can J Public Health. 1982;73(4):259-63. [pmid: 6814742].
Shephard RJ, Corey P, Renzland P, et al. The impact of changes in fitness and lifestyle upon health care utilization. Can J Public Health. 1983;74(1):51-4. [pmid: 6406030].
Shephard RJ, Corey P, Renzland P, et al. Fitness program reduces health care costs. Dimens Health Serv. 1982;59(1):14-5. [pmid: 7067929].
Spencer LS, Pratt DS, Hausman A. Using health benefits as an incentive to change employee health risks: preliminary program results. Empl Benefits J. 1996;21(2):26-9. 36. [pmid: 10157800].
Spilman MA, Goetz A, Schultz J, et al. Effects of a corporate health promotion program. J Occup Med. 1986;28(4):285-9. [pmid: 3084731].
Stevens W, Hillsdon M, Thorogood M, et al. Cost-effectiveness of a primary care based physical activity intervention in 45-74 year old men and women: a randomised controlled trial. Br J Sports Med. 1998;32(3):236-41. [pmid: 9773174].
Terry PE, Pheley AM. Health risks and educational interests in an HMO. HMO Pract. 1991;5(1):3-6. [pmid: 10108918].
Wylie-Rosett J, Swencionis C, Ginsberg M, et al. Computerized weight loss intervention optimizes staff time: the clinical and cost results of a controlled clinical trial conducted in a managed care setting. J Am Diet Assoc. 2001;101(10):1155-62. quiz 1163-4. [pmid: 11678486].