# SEARCH STRATEGIES

Search strategy for RCTs and observational studies (PubMed, May 2012)

Step | Category | Terms | Results
1 | Fitness center terms | “Health Promotion/economics”[Mesh]) OR “Insurance Benefits”[Mesh]) OR “Insurance Claim Review”[Mesh]) OR “Insurance, Health”[Mesh] | 116141
2 | Fitness center terms | “Fitness Centers”[Mesh] | 281
3 | Fitness center terms | (fitness[tiab] OR health[tiab] OR exercise[tiab] OR recreation[tiab] OR recreational[tiab] OR sports[tiab] OR aquatic[tiab]) AND (club[tiab] OR clubs[tiab] OR membership[tiab] OR memberships[tiab] OR center[tiab] OR centers[tiab] OR program[tiab] OR programs[tiab]) | 151793
4 | Fitness center terms | gym[tiab] OR gyms[tiab] OR ymca[tiab] OR “community based”[tiab] | 29217
5 | | #1 AND (#2 OR #3 OR #4) | 8751
6 | Study design terms | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] OR “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[mh] NOT humans[mh]) | 4383508
7 | | #5 AND #6 | 3601