# RESULTS

## LITERATURE FLOW

We reviewed 2,493 titles and abstracts from the electronic search, and identified an additional 42 studies from reviewing reference lists. After applying inclusion/exclusion criteria at the abstract level, 599 full-text articles were reviewed, as shown in Figure 1. Of the full-text articles, we excluded 512 that did not meet inclusion criteria.

We included 87 publications reporting on 81 group visit intervention studies focusing on education for the management of arthritis, falls prevention, asthma, COPD, hypertension, CHF/CAD, DM, or chronic pain. Tables 1, 4, 7, 10, 13, and 15 present characteristics of group visit interventions. Tables 3, 6, 9, 12, and 17 present head-to-head comparisons of multiple active group visit treatment arms as well as studies that compared individual visits to group visits.

Table 1 Characteristics of group visit interventions focusing on education for the management of arthritis or falls

Study | Sample size Setting Program name, if applicable | [underlined: Demographics]: Mean age % male % minority Mean disease duration | [underlined: GV structure]: # Visits, frequency Duration Group size | [underlined: GV content]: SME (self-mgmt) DE (didactic) EE (experiential) | [underlined: GV leaders]: Number of leaders Profession type | Comparator(s)
Arthritis
Ackerman, 2012^31^ | N=120 Australia ASMP | 65.1 yrs 40% Race NR Duration NR | 6 weekly (2h) sessions 1.5 months 4-21 patients | SME | 2 leaders Peer leader, health professional | Usual care (information book)
Barlow, 2000^32^ | N=544 UK ASMP | 58.1 yrs 16% 4% nonwhite 11 yrs with arthritis | 6 weekly (2h) sessions 1.5 months ≥10 patients | SME | 2 leaders Peer leaders | Usual care
Breedland, 2011^33^ | N=34 Netherlands FIT | 48 yrs 29% Race NR 9.7 yrs with RA | 8 weekly (1h) education 16 semi-weekly (1.5h) exercise 2 months Group size NR | DE, EE | 5 team members Psychologist, PT, OT, dietitian, social worker | Usual care
Buszewicz, 2006^34^ & Patel, 2009^35^ | N=812 UK ASMP | 68.6 yrs 37% 0.5% Caribbean black Duration NR | 6 weekly (2.5h) sessions 1.5 months 12-18 patients | SME, EE | NR | Usual care (information book)
Ettinger, 1997^22^ | N=439 US FAST | 69 yrs 30% 26% black Duration NR | 3 monthly (1.5h) sessions 18 biweekly and monthly calls 18 months 10-15 patients | DE | 2 leaders Exercise leader, nurse | Group exercise arms: GV2: 36 (1h) aerobic GV3: 36 (1h) resistance Class sizes 10-15
Freeman, 2002^36^ | N=54 UK | 51.4 yrs 15% Race NR 4.5 months with RA | 4 weekly (2h) sessions 1 month Group size NR | GV1: SME GV2: DE | 3 team members Physiotherapist, rheumatologist, psychologist | GV2
Giraudet-Le Quintrec, 2007^37^ | N=208 France | 54.8 yrs 14.1% Race NR 13.1 yrs with RA | 8 weekly (6h) sessions 1 (4h) booster after 6 months 2 months 8-10 patients | DE, EE | 10 team members Rheumatologist, rehab, specialist, dietitian, social assist., nurses, PTs, and OTs | Usual care+: Two information leaflets written by research team
Hammond, 1999^23^ | N=35 UK | 55.2 yrs 17% Race NR 9.8 yrs with RA | 4 weekly (2h) sessions Optional home visit 2 wks post 1 month 4-8 patients + spouses invited | SME | 1 leader Rheumatology OT | Usual care
Hammond, 2008^23^ | N=167 UK LMAP | 55.4 yrs 35% Race NR 7.4 yrs with RA | [underlined: GV1:] 9 sessions (2.5h) over 9 mo 12 months 6-10 patients [underlined: GV2:] 5 (2h) sessions 1.25 months 8-12 patients | GV1: SME, EE GV2: DE, EE | 3 leaders Rheumatology OT, community OT, rheumatology PT | GV2
Hewlett, 2011^38^ | N=127 UK | 59.2 yrs 27% Race NR 14 yrs with RA | [underlined: GV1:] 6 weekly (2h) sessions 1 booster session (wk 14) 1.5 months 4-9 patients [underlined: GV2:] 1 (1h) session Delivered by RA nurse | GV1: SME GV2: DE | 2 leaders Clinical psychologist, specialist OT | GV2
Kaplan, 1981^39^ | N=34 US | 48.2 yrs 0% 9% nonwhite Duration NR | [underlined: GV1:] 1 (2.5h) education session 12 weekly (1-2h) counseling 4 months [underlined: GV2:] 1 (2.5h) education session Group size NR | GV1: DE, counseling GV2: DE | 2 leaders Patient counselor, psychiatrist | GV2
Lorig, 1985^40^ | N=286 US ASMP | 67.4 yrs 17% 3% nonwhite Duration NR | 6 sessions (2h) over 4 months 4 months 15-20 patients + family | SME | 2 leaders Trained peer leaders | Usual care
Lorig, 1999^41^ | N=331 US ASMP | 62.5 yrs 16% 100% Latino Duration NR | 6 sessions (2h) over 6 weeks 1.5 months 10-15 patients and family | SME | Lay leaders | Usual care
Lorig, 2004^29^ | N=341 US ASMP | 65.2 yrs 25% 10% nonwhite Duration NR | 6 weekly (2h) sessions 1.5 months Group size NR | SME | 2 leaders Trained peer leaders | SMART group: mailed individual self-management program
Riemsma, 2003^42^ | N=218 Netherlands | 56.4 yrs 38% Race NR 11.7 yrs with RA | 5 weekly (2h) sessions 3 (2h) booster sessions 1.25 months 8 patients +/- spouses | GV1: SME, EE (patients only) GV2: SME, EE (spouses included) | 2 leaders RA nurse, nurse | GV2, and Usual care+: self-help guide
Sevick, 2009^43^ | N=316 US ADAPT | 69 yrs 28% 24% nonwhite Duration NR | [underlined: GV1:] 3x month, months 1-4 Biweekly, months 5-6 Monthly, months 7-18 18 months [underlined: GV2:] GV1 structure + 3x/week grp exercise, months 1-4 Group sizes NR | GV1: DE GV2: DE, exercise | NR | GV2, and Healthy lifestyle group: Monthly (1h) DE GV, months 1-3; monthly phone contact, months 4-5; bimonthly phone contact months 6-18
Taal, 1993^44^ | N=75 Netherlands | 49.6 yrs 20% Race NR 4.3 yrs with RA | 5 weekly (2h) sessions 1.25 months 6-8 patients | SME, EE | 2 leaders RA nurse, physiotherapist, or social worker | Usual care+: individual referral to physiotherapist
History of falls
Arnold, 2010^45^ | N=83 Canada | 74.5 yrs 29% Race NR 7.6 yrs with hip pain | [underlined: GV1:] 22 semiweekly (1.5h) sessions 2.75 months [underlined: GV2:] 22 semiweekly (.75h) sessions 2.75 months Group sizes NR | GV1: DE, EE, aquatic exercise GV2: EE, aquatic exercise | 2 leaders Aquatic fitness instructor, PT | Usual care, and GV2
Clemson, 2004^24^ | N=310 Australia Stepping On | 78.4 yrs 26% Race NR Duration NR | 7 (2h) sessions over 7 weeks 1 (1.5h) booster (after 3mo) 1.75 months 12 patients | DE, EE | OT with geriatrics experience, team of content experts for educational areas | Usual care+: ≤2 home social visits from OT student instructed not to discuss falls or falls prevention
Ryan, 1996^46^ | N=45 US | 78 yrs 0% 66% black Duration NR | 1 (1h) session 1 day 7-8 women | DE | 1 leader Nurse | Individual visit, and Usual care+: Health promotion session with no falls prevention info
Shumway-Cook, 2007^25^ | N=454 US | 75.6 yrs 23% 4% nonwhite Duration NR | 6 monthly (1h) sessions 6 months Group size NR | DE, exercise | 1 leader Nurse | Usual care (two CDC informational brochures)

Table 4 Characteristics of group visit interventions focusing on education for the management of asthma or COPD

Study | Sample size Setting Program name, if applicable | [underlined: Demographics:] Mean age % male % minority Mean disease duration | [underlined: GV structure:] # Visits, frequency Duration Group size | [underlined: GV content:] SME (self-mgmt) DE (didactic) EE (experiential) | [underlined: GV leaders:] Number of leaders Profession type | Comparator
Asthma
Wilson, 1993^48^ | N=323 US | NR | 4 weekly sessions 1 month 6-8 patients | SME | 1 leader Nurse educator | 3 comparators:; 1. individual education; 2. usual care with workbook; 3. usual care with no supplemental education
Abdulwadud, 1999^49^ | N=125 Australia Australian Asthma Management Program | Mean age 45.6 40% male Race NR Duration NR | 3 weekly sessions 3 weeks Up to 13 patients | DE | 1 leader Nurse educator | Usual care
Allen, 1995^50^ | N=116 Australia | Mean age 40 46% male Race NR Duration NR | 4 weekly sessions 4 weeks 10-12 patients | DE | 2 leaders Asthma educators | Usual care
Bolton, 1991^51^ | N=241 US | Mean age 38 34% male 67% non-white Duration NR | 3 sessions Duration NR 6-10 patients | DE | 1 leader Nurse educator | Usual care
Snyder, 1987^52^ | N=79 US Wheezers Anonymous | Mean age 28 45% male Race NR Duration NR | 2 sessions, NOS Duration NR 8-12 patients | DE | 1 leader Respiratory therapist | Usual care
COPD
Wilson, 2008^53^ | N=91 Northern Ireland | Mean age 61 48% male Race NR Duration NR Current smokers | 5 weekly sessions 5 weeks total N per session NR | SME | 1 leader Respiratory Nurse Specialist | Usual care (n=35), Individual support (n=27)
Kunik, 2008^57^ | N=238 US VAMC | Mean age 66 96% male 16% Black 3% Hispanic | 8 weekly sessions 8 weeks Up to 10 patients | SME: CBT | 1 leader Psychology intern or post-doctoral fellow with CBT experience | DE group education
Bestall, 2003^54^ | N=66 UK | Mean age 69 51% male Race NR Duration NR | 16 DE bi-weekly sessions, 8 weeks total (both groups), followed by 10 EE monthly sessions, 1 year total (exercise group only) N per session NR | DE + EE: exercise | NR | DE group education
Effing, 2011^55^ | N=159 Netherlands COPE-active | Mean age 63 58% male Race NR Duration NR 35% smokers | DE: 4 weekly sessions/1 month total; 5 patients EE: 2-3 times/week, 11 months total; 2-3 patients | DE + EE: exercise | 2 leaders Respiratory nurse Physiotherapist | DE group education
Ninot, 2011^56^ | N=45 France | Mean age 63 84% male Race NR Duration NR 26% smokers | 8 sessions, 2× week 4 weeks total | DE + EE: exercise | 2 leaders DE led by health professional, EE led by exercise trainer | Usual care

Table 7 Characteristics of group visit interventions focusing on education for the management of congestive heart failure, coronary artery disease, or hypertension

Study | Sample size Setting Program name, if applicable | [underlined: Demographics:] Mean age % male % minority Mean disease duration | [underlined: GV structure:] # Visits, frequency Duration Group size | [underlined: GV content:] SME (self-mgmt) DE (didactic) EE (experiential) | GV leaders: Number of leaders Profession type | Comparator
CHF/CAD
Smeulders, 2010^27,60^ | N=317 Netherlands CDSMP | Mean age 67 73% male Race NR Duration NR | 6 weekly sessions 6 weeks total 6-12 patients | SME | 2 leaders Cardiac nurse specialist CHF patient peer leader | Usual care
Chang, 2005^59^ | N=62 US VAMC | Mean age 69 % male NR 17% non-white Duration NR | 15 weekly sessions 15 weeks total Group size NR | DE | Experts on medical, pharmaceutical, lifestyle, nutrition, and psychosocial issues | Usual care
Moore, 2006^58^ | N=250 US CHANGE | Mean age 62 17% black 2% non-white, NOS Duration NR | 5 sessions: 3 weekly followed by 2 monthly 3 months total 6-8 patients | SME | 1 leader Cardiac nurse | Usual care
Hypertension
Baghianimoghadam, 2010^67^ | N=150 Iran | Mean age 57.9 39% male Race NR Duration 6.77 yr | Frequency NR 2 months total Group size NR | DE + EE | 1 leader Health education researcher | Usual care
Nessman, 1980^62^ | N=52 US VAMC | Mean age 55 10% black 16% Mexican-American Duration NR | 8 weekly sessions 8 weeks total Group size NR | DE | 2 leaders Nurse, psychologist | Informational control (audiotape)
Rujiwatthanakorn, 2011^63^ | N=96 Thailand | Mean age 61 40% male Race NR Duration NR | 3 sessions 8 weeks total 6-7 patients Duration NR | SME | 1 leader Nurse | Usual care
Balcazar, 2009^64^ | N=98 US | Mean age 53 21% male 100% Mexican-American, 87% born in Mexico Duration NR | 4 sessions at weeks 1, 2, 3, 8 8 weeks total 15-20 patients | DE | 2 leaders Promotoras (Mexican-American community health workers) | Informational control
Figar, 2006^65^ | N=60 Argentina PEM | Mean age 69 57% male Duration NR | 4 weekly sessions 4 weeks 10 patients | SME | Physicians with experience in HTN education/management | DE
Scala, 2008^66^ | N=292 Italy | Mean age 62 42% male Race NR Duration NR | 3 sessions 4 months total 4-5 patients | SME | 1 leader Moderator, tutor assistants | Informational control
Svetkey, 2009^26^ | N=574 US | Mean age 60.5 39% male 37% black 1% Hispanic Duration NR | 20 weekly sessions 6 months total 10-15 patients | SME | 2 leaders Behavioral interventionist, assistants (community health advisors) | Usual care

Table 10 Characteristics of group visit interventions focusing on education for the management of diabetes mellitus

Study | Population: Setting Program name, if applicable | [underlined: Demographics:] Mean age % male % minority Mean disease duration | [underlined: GV structure:] # Visits, frequency Duration Group size | [underlined: GV content:] SME (self-mgmt) DE (didactic) EE (experiential) | [underlined: GV leaders:] Number of leaders Profession type | Comparator
Adolfsson, 2007^75^ | N=101 Sweden | 63.1 yrs 54% Minority NR 6.6 yrs with DM | 4 (2.5h) sessions 1 booster (2.5h) within 7 months 5-8 patients | DE | 7 physicians and 12 diabetes specialist nurses | Usual care
Anderson, 2005^76^ | N=239 US | 61 yrs 18% 96% minority 8.5 yrs with DM | 6 weekly (2h) sessions 1.5 months Group size NR | SME | Certified diabetes educators | Usual care
Brown, 2002^15^ | N=256 US The Starr County Border Health Initiative | 54 yrs 36% Race NR 7.85 yrs with DM | 12 weekly, 12 biweekly, 3 monthly (2h) sessions 12 months Group size NR | DE, EE | Bilingual Mexican American nurses, dietitians, local community workers | Usual care
Brown, 2005^16,*^ | N=216 US The Starr County Border Health Initiative | 49.6 yrs 40% Race NR 5.1 yrs with DM | [underlined: GV1:] 3 weekly, 12 biweekly, 3 monthly (2h) sessions 12 months Group size NR [underlined: GV2:] 8 weekly (2h) sessions 3 support @ 3, 6, and 12 months 8 patients | DE, EE | Bilingual Mexican American nurses, dietitians, local community workers | GV2
De Greef, 2011^73^ | N=67 Belgium | 67.4 yrs 70.1% Minority NR 64.5% diagnosed <5 yr | 3 (1.5h) sessions every 3wks 3 months Group size NR | SME | Clinical psychologist | Usual care; individual visit arm: 3 (15min) visits with similar content to GV
Deakin, 2006^71,*^ | N=314 UK | 61.6 yrs Gender NR Race NR 6.7 yrs with DM | 6 weekly (2h) sessions 1.5 months 16 patients (mean) | SME | 1 diabetes research dietitian/educator | Usual care+: diabetes education and review with individual appointments with a dietitian (30 min), practice nurse (15 min) and physician (10 min)
Dejesus, 2009^77,*^ | N=54 US | 76% aged 60+ 48% Race NR Duration NR | 1 session 7 patients | DE | Diabetes nurse educator | Usual care
Hornsten, 2008^17^ | N=104 Sweden | 63 yrs 54% Race NR All diagnosed ≤ 2yrs | 10 (2h) sessions over 9 mo 9 months 5-8 patients | SME | Diabetes nurses | Usual care
Khunti, 2012^68^ Davies, 2008^70^ | N=824 UK DESMOND | 59.5 yrs 55% male 6% minority Duration NR | 1 (6h) session 1 day or 2 half-days Group size NR | SME | Healthcare professional | Usual care+: (resources to provide equivalent contact time as intervention)
Kulzer, 2007^72,*^ | N=193 Germany | Mean age 55.6 50.3% male Race NR Mean duration 6.6 yrs | GV1: 4 DE sessions GV2: 12 SME sessions GV3: 6 SME sessions + 6 IV Duration NR Group size 6-10 | GV1: DE GV2: SME | Health psychologist | Self-management education - 6 90 min group lessons and 6 90 min individual lessons
Lorig, 2009^69^ | N=345 US DSMP | 66.55 yrs 35.7% 32.7% minority Duration NR | 6 weekly (2.5h) sessions 1.5 months 10-15 patients | SME | Peer leaders | Usual care
Lujan, 2007^78^ | N=150 US | 58 yrs 20% 100% Mexican origin Duration NR | 8 weekly (2h) sessions 2 months 6 patients (English class) 23 patients (Spanish class) | DE | 2 leaders Promotoras, nurses, dietitians, social workers | Usual care (2 pamphlets)
Melkus, 2010^13,*^ | N=109 UK | 46 yrs 0% 100% minority Duration NR | 11 weekly (l-2h) sessions 3 months Group size NR | SME | Nurse practitioner | Culturally neutral group DE (10 weekly sessions)
Miller, 2002^79^ | N=98 US | 72.5 yrs 47% 17% black 7.2 yrs | [underlined: GV1:] 10 weekly (1.5-2h) sessions 2.5 months Group size NR [underlined: GV2:] Offered 6 (2h) sessions Group size NR | GV1: DE, EE GV2: DE | Dietitian | GV2 (participants were mailed printed material if they did not attend the group session)
Philis-Tsimikas, 2011^18^ | N=207 US Project Dulce | 50.7 years 29% male Minority NR Duration NR | 8 weekly (2h) sessions 8 monthly support groups 10 months Group size NR | DE | Trained peer educator | Usual care
Raji, 2002^80,*^ | N=106 US VAMC | Mean age 60 yrs 99% male Race NR Duration NR | 4 daily sessions 4 sequential days 4-6 patients | DE | Physician, nurse, nutritionist, pharmacist, exercise physiologist, social worker, and diabetes educator | 2 comparators: passive education and no-intervention
Rickheim, 2002^74,*^ | N=170 US | Mean age 52.5 34% male Race 7% non-white? Duration 0.9 yrs | 4 sessions (at 0, 2 wks, 3 mo, 6 mo) 6 months total | DE | A diabetes nurse specialist (RN) and diabetes nutrition specialist (RD) | Individual education sessions
Rosal, 2011^19^ | N=252 US Latinos en Control | 83.7% aged 45+ 23.4% 87.7% minority 31.3% diagnosed <5 yr | 12 weekly + 8 monthly First session (1h) individual Remaining (2.5h) group 11 months Group size NR | SME, EE | Nutritionist or health educator and lay leader or 3 supervised lay leaders | Usual care
Rygg, 2012^21^ | N=146 Norway | 66 yrs 55% 0% 5 yrs with DM | 3 biweekly (5h) sessions 1.25 months 8-10 patients | DE, EE | Diabetes nurses; also included physician, physiotherapist, nutritionist, and lay person | Usual care
Sarkadi, 2004^81,*^ | N=77 Sweden | Mean age 66 % male NR Race NR Duration 5.9 yrs treatment; 2.6 yrs control | 12 monthly sessions 1 year total Group size NR | DE | Pharmacists trained to be facilitators, and a nurse specialist | Usual care
Scain, 2009^82^ | N=104 Brazil | 59 yrs 47% 9.4% black 10.5 yrs | 4 weekly (2h) sessions 1 month 8-10 patients | DE | NR | Usual care
Schillinger, 2009^30^ | N=339 US IDEALL | 56.1 years 41% male 92.3% minority Duration NR | 9 monthly (1.5h) sessions 9 months 6-10 patients | SME | 2 leaders Physician and language-concordant health educator | Usual care; automated telephone self-management support group (39 weekly, automated calls over 9 months, nurse phone follow-up)
Sharifirad, 2012^83^ | N=97 Iran BASNEF | 67.05 yrs 35% Minority NR 14 yrs with DM | 4 (70min) sessions 1 month Group size NR | DE | Physician, specialist of endocrine disorder, diabetes nurse, and nutritionist | Usual care
Sperl-Hillen, 2011^84,*^ | N=623 US IDEA | Mean age 61.8 50.6% male 22.1% Hispanic 5.5% Black Duration 11.7 yrs | 4 weekly sessions 4 weeks total 1-10 patients (mean 5) | DE | Nurses and dietitians trained to facilitate GE sessions | 3 individual education sessions at 1-month intervals
Steed, 2005^85^ | N=127 UK UCL-DSMP | 59.8 yrs 71.2% male 51% minority 10.8 years | 5 weekly (2.5h) sessions 1 booster (2.5h) @ 3 months 1.25 months Group size NR | SME | Diabetes specialist nurses and dietitians | Usual care
Surwit, 2002^20,*^ | N=108 US | Mean age 57.4 58.3% male 8.3% Black 1% Asian | 5 weekly sessions 5 weeks total Group size NR | EE | NR | DE group visits
Toobert, 2011^86-87^ | N=280 US Viva Bien! | 57.11 yrs 0% 100% minority 10.4 yrs with DM | 2.5-day retreat + 36 weekly and biweekly sessions 12 months Group size NR | DE, EE | Bilingual physician, dietitian, exercise instructor, bilingual facilitator | Usual care
Weinger, 2011^14,*^ | N=222 US | 52.5 yrs 49.5% 10.3% minority 17.2 yrs with DM | 5 (2h) sessions over 6 wks 1.5 months Group size NR | SME | Certified diabetes educator | Unlimited access to individual DM nurse and dietitian visits
Zapotoczky, 2001^88,*^ | N=34 Austria | Mean age 62 yrs 36% male | 12 monthly sessions 1 year total 18 patients | DE | Clinical dietitian | All subjects received 4-wk group education. Controls received usual care with no further group education.

* Not included in meta-analysis.

Table 13 Characteristics of group visit interventions focusing on education for the management of chronic conditions in populations with multiple disease groups

Study | Sample size Setting Program name, if applicable | [underlined: Demographics:] Mean age % male % minority Mean disease duration | [underlined: GV structure:] # Visits, frequency Duration Group size | [underlined: GV content:] SME (self-mgmt) DE (didactic) EE (experiential) | [underlined: GV leaders:] Number of leaders Profession type | Comparator
Lorig, 1999^92^ | N=952^*^ US CDSMP | Mean age 65 35% male 9.7% non-white Duration NR (heart disease, lung disease, arthritis, and stroke) | 7 weekly sessions 7 weeks total 10-15 patients | SME | 2 trained peer leaders | Usual care
Lorig, 2003^91^ | N=551 US CDSMP (Spanish) | Mean age 57 21% male Race NR Duration NR | 6 weekly sessions 6 weeks total 10-15 patients | SME | 2 trained peer leaders | Usual care
Fu, 2003^90^ | N=954 China CDSMP | Mean age 64 29% male Race NR Duration NR | 7 weekly sessions 7 weeks total Group size NR | SME | 2 trained peer volunteer leaders | Usual care
Elzen, 2007^89^ | N=136 Netherlands CDSMP | Mean age 68 37% male Race NR Duration NR | 6 weekly sessions 6 weeks 10-13 patients | SME | 2 psychologists or 1 psychologist plus peer leader | Usual care

* N=1,128 in the intent-to-treat analysis. Results are reported as being similar in ITT and per-protocol analysis, but full results reporting only available for the group completing the study.

Table 15 Characteristics of group visit interventions focusing on education for the management of chronic pain

Study | Sample size Setting Program name, if applicable | [underlined: Demographics:] Mean age % male % minority Mean disease duration | [underlined: GV structure:] # Visits, frequency Duration Group size | [underlined: GV content:] SME (self-mgmt) DE (didactic) EE (experiential) | [underlined: GV leaders:] Number of leaders Profession type | Comparator
Chronic Pain
Ersek, 2003^97^ | N=45 US | Age 81.9 Gender 13% Race 84.71% Caucasian Duration NR | 7 weekly sessions 8 weeks 3-8 patients | SME | 2 leaders Doctoral-level health providers | Receipt of an educational booklet on pain
Gustavsson, 2010^98^ | N=156 Sweden PASS | Age 45.7 Gender 11% Race NR Duration NR | 7 weekly sessions 7 weeks + 1 booster at week 20 Group size NR | SME, EE | 1 leader Physical therapists | Individual physical therapy sessions
Haugli, 2000 & Haugli, 2003^28-95^ | N=174 Norway | Age 43.08 Gender 2.27% Race NR Duration 9.89 years | 12 every-other-week sessions 9 months (including a summer break) 6-10 patients | SME | 2 leaders Nurses, physicians physiotherapists | Usual care
Vlaeyen, 1996^96^ | N=131 Netherlands | Age 44 Gender 12% Race NR Duration 10.2 years | 12 sessions 6 weeks Maximum of 6 patients | GV1: SME, EE GV2: DE, EE | Rehabilitation staff, psychologist | Usual care

Table 3 Summary of findings from head-to-head group visit interventions and group vs. individual visit interventions for arthritis or falls

Study | Arm 1 | Arm 2 | % Participation^*^/% Loss to follow-up^†^ | Study quality (Good/Fair/Poor) | Key findings
Arthritis
Hewlett, 2011^38^ | GV1 (7 SME sessions) | GV2 (1 DE session) | 15 / 24 | Good | Beneficial effect of cognitive behavior therapy relative to didactic-only single session GV assessed at 4.5 months
Ettinger, 1997^22^ | GV1 (3 DE sessions) | GV2 aerobic exercise (36 classes) | 53 / 17 | Fair | Beneficial effect of either exercise group vs. education group on pain, disability, and functional performance. Dose response for patients who completed more sessions of either exercise program.
Ettinger, 1997^22^ | GV1 (3 DE sessions) | GV3 resistance exercise (36 classes) | 53 / 17 | Fair | Beneficial effect of either exercise group vs. education group on pain, disability, and functional performance. Dose response for patients who completed more sessions of either exercise program.
Freeman, 2002^36^ | GV1 (4 SME sessions) | GV2 (4 DE sessions) | 94 / 23 | Fair | Cognitive-behavioral education program did not significantly improve pain or self-efficacy for patients newly diagnosed with RA.
Hammond, 2008^47^ | GV1 (9 SME, EE sessions) | GV2 (5 DE, EE sessions) | 46 / 37 | Fair | GV1 was effective in improving short-term pain, functional disability, self-efficacy, and reducing physician visits compared to GV2. Longer-term benefits for GV1 for pain, and maintained functional ability compared to declines in GV2.
Kaplan, 1981^39^ | GV1 (13 DE, group counseling sessions) | GV2 (1 DE session) | NR / 35 | Poor | Combination of education and short-term group counseling led to improved knowledge and self-esteem.
Lorig, 2004^29^ | GV (6 SME sessions) | Mailed individual program | 84 / 32 | Good | Both programs show moderate improvements in self-efficacy, pain, and disability outcomes. Earlier advantages of mailed program narrowed after 3 yrs. GV program had decreased physician visits compared with mailed program.
Riemsma, 2003^42^ | GV1 (8 SME, EE sessions) Patients only | GV2 (8 SME, EE sessions) Patients and significant others | 26 / 17 | Fair | Participation of significant others led to decreases in self-efficacy for coping with other symptoms compared to improvements in patients participating without their partners.
Sevick, 2009^43^ | GV1 (28 DE sessions) | GV2 (76 DE, exercise sessions) | NR / 20 | Good | GV2 was the most effective in improving function and pain when costs were not considered. GV1 was the most cost-effective for reducing weight; GV2 was the most cost-effective for improving function.
Sevick, 2009^43^ | GV1 (28 DE sessions) | GV3 (3 DE sessions) | NR / 20 | Good | GV2 was the most effective in improving function and pain when costs were not considered. GV1 was the most cost-effective for reducing weight; GV2 was the most cost-effective for improving function.
History of falls
Arnold, 2010^45^ | GV1 (22 DE, EE, aquatic exercise classes) | GV2 (22 EE, aquatic exercise classes) | 55 / 23 | Fair | Combination of aquatic exercise and education resulted in improvements in functional performance vs. aquatic exercise alone.
Ryan, 1996^46^ | GV (1 DE) | Individual (1 DE) | NR / NR | Poor | Small study. Control group experienced the most falls in the post period.

* Defined as percent eligible for enrollment among those invited to participate.

† Defined as percent lost to follow-up among those randomized.

Table 6 Summary of findings from head-to-head group visit interventions and group vs. individual visit interventions for the management of asthma or COPD

Study | Arm 1 | Arm 2 | % Participation†/% Loss to follow-up‡ | Study quality (Good/Fair/Poor) | Key findings
Asthma
Wilson, 1993^48^ | GV (3 SME sessions) | IV (3-5 weekly SME sessions) | 56 / 14 | Fair | No significant differences between GV and IV GV and IV were equally effective compared with UC. Reduced bother and improved MDI technique observed with both small group and individual education.
COPD
Bestall 2003^54^ | GV (16 DE + 26 EE sessions: exercise) | GV (16 DE sessions) | NR / 16 | Fair | Compared with DE alone, pts in exercise group had improved exercise capacity (shuttle walking distance) that lasted 6 months. For QoL (CRQ, SGRQ) there were mixed results at 6 months, and no differences between groups at 1 year.
Effing 2011^55^ | GV (4 DE + up to 120 EE sessions) | GV (4 DE sessions) | 41 / 11 | Fair | COPE-active group experienced an improvement in maximal exercise capacity compared to the steady decline in the control group.
Kunik, 2008^57^ | GV (8 DE sessions) | GV (8 SME sessions: CBT) | 19 / 55 | Good | CBT and COPD education groups were comparable and significantly improved QoL, anxiety, depression, and 6MWD, with no significant differences between groups, and improvement was maintained till the end of the study (52 weeks).

Table 9 Summary of findings from head-to-head group visit interventions and group vs. individual visit interventions for the management of hypertension

Study | Arm 1 | Arm 2 | % Participation / % Attrition | Study quality | Key findings
Figar, 2006^65^ | GV (4 SME sessions) | GV (4 DE sessions) | NR / 17 | Good | More SME patients had controlled BP (defined as the proportion of patients with mean 24-h BP <140/90 mm Hg) compared with DE: 70% vs 44%, p=0.04. No significant reductions in SBP or DBP in either group.

Table 12 Summary of findings from head-to-head group visit interventions and group vs. individual visit interventions for the management of diabetes mellitus

Study | Arm 1 | Arm 2 | % Participation^1^/% Loss to follow-up^2^ | Study quality (Good/Fair/Poor) | Key findings
Deakin, 2006^71^ | GV (6 SME) | Individual (3 DE) | 20 / 32 | Fair | Significant improvements with group compared with individual visits in glycemic control, total cholesterol level, body weight, BMI and waist circumference, reduced requirement for diabetes medication, increased consumption of fruit and vegetables, enjoyment of food, knowledge of diabetes, self-empowerment, self-management skills and treatment satisfaction.
De Greef, 2011^73^ | GV (3 SME) | Individual (3 SME) | 78 / 5 | Good | No improvement in biophysical health outcomes for patients in the GV arm compared to individual visit arm. Individual visit participants showed significant improvements in waist circumference, FBG, HbA1c, and total cholesterol compared to control arm.
Kulzer, 2007^72^ | GV1 (4 DE) | GV2 (12 SME) GV3 (6 Group + 6 individual SME) | 50 / 6 | Fair | GV2 (SME) had significantly lower HbA1c at 15 months compared with both GV1 (DE) and GV3 (group + individual SME). GV2 (SME) also had significant improvements in BMI, anxiety, and exercise relative to GV1 (DE).
Melkus, 2010^13^ | GV1 (11 culturally relevant SME) | GV2 (10 culturally neutral DE) | NA / 11 | Fair | Both arms had significant, similar reductions in HbA1c at 24 months. The culturally relevant SME group had significantly lower levels of diabetes-related emotional distress at 24 months compared with the culturally neutral DE group.
Miller, 2002^79^ | GV1 (10 DE, EE) | GV2 (6 DE, or mailed materials) | NA / 6 | Fair | Intense nutrition education GV improved glycemic control
Rickheim, 2002^74^ | GV (4 DE) | Individual (4 DE) | NR / 46 | Poor | Individual and group education resulted in similar improvements at 6 months in HbA1c, weight, BMI, health-related QOL, attitudes, and medication regimen.
Schillinger, 2009^30^ | GV (9 SME) | ATSM: automated telephone self-management (39 SME calls) | 73 / 10 | Fair | No statistical differences between GV and ATSM arms in self-efficacy, or quality of life (physical). Improvement for ATSM relative to GV in quality of life (mental).
Sperl-Hillen, 2011^84^ | GV (4 DE) | Individual (3 DE); Usual care | 82 / 2 | Fair | HbA1c deceased significantly more with individual DE compared with group DE and usual care. Individual DE significantly reduced distress (PAID) and increased self-efficacy compared with group DE.
Surwit, 2002^20^ | GV1 (5 DE) | GV2 (5 DE + EE) | NA / 24 | Poor | At 1-year follow-up, patients who received training in stress management in addition to DE had a 0.5% reduction in HbA1c relative to DE alone. No differences between groups in anxiety (STAI) or psychological distress (GHQ; PSS) measures.
Weinger, 2011^14^ | GV (5 SME) | Individual DE (unlimited access to DM nurse and dietitian visits) | 89 / 3 | Fair | GV (SME) had significantly greater reduction in HbA1c levels over 1 year compared with individual DE. No differences in QOL, and self-efficacy measures.
Zapotoczky, 2001^88^ | GV1 (4wk + 12mo DE) | GV2 (4wk DE) | 100 / 0 | Poor | All subjects received 4-wk group education. GV2 received usual care with no further group education. Significant reductions in HbA1c and body weight over 1 year in GV1 (12-month continuation DE) compared with GV2.

1 % participation from consented=#eligible/#invited

2 % lost to follow-up of those randomized

Table 17 Summary of findings from head-to-head group visit interventions and group vs. individual visit interventions for the management of chronic pain

Study | Arm 1 | Arm 2 | Key findings
Chronic Pain
Ersek, 2003^97^ | GV (7 SME sessions) | Educational booklet on pain | There was a significant improvement in physical role functioning and in pain intensity directly following treatment, but not 3 months after treatment, though no significant effect was noted for other primary outcome variables including physical functioning, activity interference, and depression.
Vlaeyen, 1996^96^ | GV (12 SME, EE, DE sessions) | GV (12 DE, EE sessions) | Significant improvement of knowledge, pain coping, pain control, and relaxation for both GV groups compared to control at immediate follow-up; non-significant differences between GV groups at 6 and 12-month follow-up on all primary outcomes.
Gustavsson, 2010^98^ | GV (8 session, SME, EE) | Individual physical therapy | GV was positively associated with most assessed outcomes including pain coping, pain control, catastrophizing, pain scores, and anxiety, though effects on depression were non-significant.

Figure 2 Literature Flow – Group visits focusing on education for the management of chronic conditions in adults: A systematic review

## Findings by Key Question

### Key Question 1 In adults with chronic medical conditions, how do group visits compared to usual care affect the following: (1) medication adherence, biophysical markers; (2) symptom status, functional status, mortality, patient satisfaction; (3) utilization of medical resources, health care costs; (4) adverse outcomes?

Tables 2, 5, 8, 11, 14, and 16 present findings of effectiveness of group visit interventions compared to usual care in the short (0-3 months), medium (4-6 months), long-term (7-12 months), or very long-term (13+ months). In addition, we present a full accounting of the total number of outcomes examined by studies in Appendix Table C2. Appendix E provides a glossary of acronyms and abbreviations for outcomes used in the included studies. We present findings from meta-analyses of mean change in HbA1c following group visit intervention for patients with diabetes mellitus in Figures 3 to 6.

Table 2 Findings from interventions reporting standardized or validated measures that compare group visits to control, stratified by clinical areas of arthritis or falls

Study | Outcome | Findings by time period^*^ | | | | GV duration | # Sessions | % Participation^†^/% Loss to follow-up^‡^ | Study quality
Study | Outcome | 0-3 mo | 4-6 mo | 7-12 mo | 13+ mo | GV duration | # Sessions | % Participation^†^/% Loss to follow-up^‡^ | Study quality
Arthritis
Self-efficacy
Ackerman, 2012^31^ | heiQ | + | NR | ≈ | NR | 1.5 mo | 6 | 25 / 22 | Poor
Barlow, 2000^32^ | ASES (pain) | NR | + | NR | NR | 1.5 mo | 6 | NR / 22 | Fair
Breedland, 2011^33^ | ASES | ≈ | NR | NR | NR | 2 mo | 24 | NR / 6 | Good
Buszewicz, 2006^34^ | ASES | NR | + | + | NR | 1.5 mo | 6 | 30 / 24 | Fair
Giraudet-Le Quintrec, 2007^37^ | AHI (coping) | NR | NR | + | NR | 2 mo + booster @ 4 mo | 9 | 18 / 9 | Fair
Hammond, 1999^23^ | ASES | Unclear | NR | NR | NR | 1 mo | 4 | NR / 31 | Fair
Lorig, 1985^40^ | Knowledge + self-management scale | NR | + | NR | NR | 4 mo | 6 | NA / 16 | Fair
Lorig, 1999^41^ | ASES | NR | + | NR | NR | 1.5 mo | 6 | NR / 17 | Poor
Riemsma, 2003^42^ | ASES | ≈ | ≈ | ≈ | NR | 1.25 mo+ booster @ 3, 6, 9 mo | 8 | 26 / 17 | Fair
Taal, 1993^44^ | ASES (pain, other) | ≈ | ≈ | NR | ≈ | 1.25 | 5 | 54 / 24 | Poor
Taal, 1993^44^ | ASES (function) | + | ≈ | NR | + | 1.25 | 5 | 54 / 24 | Poor
Quality of life/functional status
Ackerman, 2012^31^ | AQoL | ≈ | NR | ≈ | NR | 1.5 mo | 6 | 25 / 22 | Fair
Barlow, 2000^32^ | HADS (depression) | NR | + | NR | NR | 1.5 mo | 6 | NR / 22 | Fair
Breedland, 2011^33^ | Dutch AIMS2 | ≈ | NR | NR | NR | 2 mo | 24 | NR / 6 | Good
Buszewicz, 2006^34^ | SF-36 | NR | ≈ | ≈ | NR | 1.5 mo | 6 | 30 / 24 | Fair
Giraudet-Le Quintrec, 2007^37^ | AIMS2 | NR | NR | ≈ | NR | 2 mo + booster @ 4 mo | 9 | 18 / 9 | Fair
Hammond, 1999^23^ | HAQ (function) | Unclear | NR | NR | NR | 1 mo | 4 | NR / 31 | Fair
Lorig, 1985^40^ | HAQ (disability) | NR | ≈ | NR | NR | 4 mo | 6 | NA / 16 | Fair
Lorig, 1999^41^ | HAQ (disability) | NR | + | NR | NR | 1.5 mo | 6 | NR / 17 | Poor
Patel, 2009^35^ | SF-36 / QALY | ≈ | ≈ | ≈ | NR | 1.5 mo | 6 | 30 / 24 | Fair
Riemsma, 2003^42^ | Dutch AIMS2 | ≈ | ≈ | ≈ | NR | 1.25 mo+ booster @ 3, 6, 9 mo | 8 | 26 / 17 | Fair
Taal, 1993^44^ | Dutch AIMS | ≈ | ≈ | NR | ≈ | 1.25 mo | 5 | 54 / 24 | Poor
Biophysical and performance measures
Breedland, 2011^33^ | VO_2_ max | + | NR | NR | NR | 2 mo | 24 | NR / 6 | Good
Utilization
Ackerman, 2012^31^ | MD visits | ≈ | NR | ≈ | NR | 1.5 mo | 6 | 25 / 22 | Fair
Barlow, 2000^32^ | MD visits | NR | ≈ | NR | NR | 1.5 mo | 6 | NR / 22 | Fair
Buszewicz, 2006^34^ | MD visits | NR | NR | ≈ | NR | 1.5 mo | 6 | 30 / 24 | Fair
Lorig, 1985^40^ | MD visits | NR | ≈ | NR | NR | 4 mo | 6 | NA / 16 | Fair
Lorig, 1999^41^ | MD visits | NR | + | NR | NR | 1.5 mo | 6 | NR / 17 | Poor
Patel, 2009^35^ | MD/outpatient visits | NR | ≈ | ≈ | NR | 1.5 mo | 6 | 30 / 24 | Fair
History of falls
Self-efficacy
Arnold, 2010^45^ | ABC (falls efficacy) | + | NR | NR | NR | 2.75 mo | 22 | 55 / 23 | Fair
Clemson, 2004^24^ | MES | NR | NR | NR | + | 1.75 mo + booster @ 3 mo | 8 | NA / 15 | Good
Quality of life/functional status
Arnold, 2010^45^ | AIMS2 | ≈ | NR | NR | NR | 2.75 mo | 22 | 55 / 23 | Fair
Clemson, 2004^24^ | SF-36 | NR | NR | NR | ≈ | 1.75 mo + booster @ 3 mo | 8 | NA / 15 | Good
Biophysical and performance measures
Arnold, 2010^45^ | TUG (dual task) | ≈ | NR | NR | NR | 2.75 mo | 22 | 55 / 23 | Fair
Clemson, 2004^24^ | Fall events | NR | NR | NR | + | 1.75 mo + booster @ 3 mo | 8 | NA / 15 | Good
Ryan, 1996^46^ | Fall events | Unclear | NR | NR | NR | 1 day | 1 | NR / NR | Poor
Shumway-Cook, 2007^25^ | Fall events | NR | NR | ≈ | NR | 6 mo | 6 | 88 / 5 | Fair
Shumway-Cook, 2007^25^ | TUG | NR | NR | + | NR | 6 mo | 6 | 88 / 5 | Fair

* Symbols pertain to statistical significance (p<0.05), as follows: ≈ denotes no difference between arms; + denotes in favor of the GV arm; - denotes in favor of the C arm; NR = data not reported for time period.

† Defined as percent eligible for enrollment among those invited to participate.

‡ Defined as percent lost to follow up among those randomized.

Table 5 Findings from interventions comparing group visits to usual care control for the management of Asthma or COPD, stratified by clinical area and outcome category

Study | Outcome | Findings by time period^*^ | | | | GV duration | #visits | % Participation^†^/% Loss to follow-up^‡^ | Study quality
Study | Outcome | 0-3 mo | 4-6 mo | 7-12 mo | 13+ mo | GV duration | #visits | % Participation^†^/% Loss to follow-up^‡^ | Study quality
Asthma
Self-efficacy
Abdulwadud, 1999^49^ | Asthma Attitudes and Beliefs Questionnaire | NR | ≈ | NR | NR | 3 weeks | 3 | 71 / 38 | Poor
Quality of life/functional status
Abdulwadud, 1999^49^ | AQLQ | + | ≈ | NR | NR | 3 weeks | 3 | 71 / 38 | Poor
Wilson, 1993^48^ | Asthma bother scale | NR | NR | + | NR | 3-4 months | 4 | 56 / 14 | Fair
Utilization
Wilson, 1993^48^ | Acute visits | NR | NR | ≈ | + | 1 month | 4 | 56 / 14 | Fair
Bolton, 1991^51^ | ER visits | NR | + | ≈ | NR | NR | 3 | 45 / 7 | Fair
COPD
Quality of life/functional status
Wilson, 2008^53^ | Smoking cessation | NR | NR | ≈ | NR | 5 weeks | 5 | 60 / NR | Fair
Ninot, 2011^56^ | SGRQ | NR | NR | ≈^§^ | NR | 4 weeks | 8 | NA / 16 | Good
Biophysical and performance measures
Kunik, 2008^57^ | 6MWD | ≈ | NR | ≈ | NR | 8 weeks | 8 | 19 / 55 | Good
Ninot, 2011^56^ | 6MWD | NR | NR | + | NR | 4 weeks | 8 | NA / 16 | Good
Utilization
Ninot, 2011^56^ | Days in hospital for COPD admission | NR | NR | ≈ | NR | 4 weeks | 8 | NA / 16 | Good

* Symbols pertain to statistical significance (p<0.05), as follows: ≈ denotes no difference between arms; + denotes in favor of the GV arm; - denotes in favor of the C arm; NR = data not reported for time period.

† Defined as percent eligible for enrollment among those invited to participate.

‡ Defined as percent lost to follow up among those randomized.

§ There was a greater decrease in total SGRQ score in GV compared with usual control, but the difference did not reach statistical significance (p=0.06). There was a significantly greater reduction on the SGRQ Symptom subscale associated with GV, but no significant differences in the Activity or Impacts subscales.

Table 8 Findings from interventions comparing group visits to usual care control for the management of CHF/CHD/Hypertension, stratified by clinical area and outcome category

Study | Outcome | Findings by time period* | | | | GV duration | Visits | % Participation†/% Loss to follow-up‡ | Study quality
Study | Outcome | 0-3 mo | 4-6 mo | 7-12 mo | 13+ mo | GV duration | Visits | % Participation†/% Loss to follow-up‡ | Study quality
CHF/CAD
Self-efficacy
Smeulders, 2010^27,60^ | GSES | ≈ | ≈ | ≈ | NR | 6 weeks | 6 | 44 / 16 | Good
Smeulders, 2010^27,60^ | Cardiac self-efficacy: KCCQ | ≈ | ≈ | ≈ | NR | 6 weeks | 6 | 44 / 16 | Good
Smeulders, 2010^27,60^ | Cognitive Symptom Scale | + | ≈ | ≈ | NR | 6 weeks | 6 | 44 / 16 | Good
Moore, 2006^58^ | Index of Self-Regulation; Exercise Barriers and Adherence Self-Efficacy Scale | ≈ | NR | NR | ≈ | 3 months | 5 | 50 / 19 | Fair
Quality of life/functional status
Smeulders, 2010^27,60^ | Cardiac-specific QOL | + | ≈ | ≈ | NR | 6 weeks | 6 | 44 / 16 | Good
Smeulders, 2010^27,60^ | HADS - Anxiety | ≈ | ≈ | ≈ | NR | 6 weeks | 6 | 44 / 16 | Good
Smeulders, 2010^27,60^ | HADS - Depression | ≈ | ≈ | ≈ | NR | 6 weeks | 6 | 44 / 16 | Good
Chang, 2005^59^ | Minnesota Living with Heart Failure Questionnaire | NR | ≈ | NR | NR | 15 weeks | 15 | 17 / 13 | Fair
Biophysical
Smeulders, 2010^27,60^ | Biophysical: BMI | ≈ | ≈ | ≈ | NR | 6 weeks | 6 | 44 / 16 | Good
Hypertension
Biophysical
Nessman, 1980^62^ | SBP and DBP | + | + | NR | NR | 8 weeks | 4 | 36 / 0 | Poor
Rujiwatthanakorn, 2011^63^ | SBP and DBP | + | NR | NR | NR | 8 weeks | 3 | 70 / 12 | Poor
Balcazar, 2009^64^ | BP, BMI & Waist circumference | ≈ | NR | NR | NR | 8 weeks | 4 | NR / 0 | Poor
Scala, 2008^66^ | SBP and DBP | NR | NR | NR | + | 4 months | 3 | NR / 42 | Poor
Svetkey, 2009^26^ | SBP and DBP | NR | + | NR | ≈ | 6 months | 20 | 56 / 12 | Good

Table 11 Findings from interventions reporting standardized or validated measures that compare group visits to usual care in the management of diabetes mellitus

Study | Outcome | Findings by time period^*^ | | | | GV duration | # Sessions | % Participation^†^/% Loss to follow-up^‡^ | Study quality (Good/Fair/Poor)
Study | Outcome | 0-3 mo | 4-6 mo | 7-12 mo | 13+ mo | GV duration | # Sessions | % Participation^†^/% Loss to follow-up^‡^ | Study quality (Good/Fair/Poor)
Self-efficacy
Brown, 2002^15^ | Study specific health belief scale (control) | ≈ | NR | ≈ | NR | 12 months | 27 | NR / NR | Poor
Adolfsson, 2007^75^ | Study specific questionnaire | NR | NR | ≈ | NR | 7 months (max) | 5 | 53 / 13 | Fair
Khunti, 2012^68^ Davies, 2008^70^ | IPQ-R | + | + | + | + | 1 day or 2 half-days | 1 | NA / 11 | Good
Lorig, 2009^69^ | PAM | NR | + | NR | NR | 1.5 months | 6 | NA / 15 | Fair
Lorig, 2009^69^ | Diabetes Self-Efficacy scale | NR | + | NR | NR | 1.5 months | 6 | NA / 15 | Fair
Lujan, 2007^78^ | DHBM | ≈ | +^§^ | NR | NR | 2 months | 8 | NR / 6 | Fair
Rosal, 2011^19^ | Study specific scale (diet & physical activity change) | NR | + | + | NR | 11 months | 19 | 57 / 16 | Fair
Rygg, 2012^21^ | PAM | NR | ≈ | ≈ | NR | 1.25 months | 3 | 91 / 9 | Fair
Schillinger, 2009^30^ | DQIP | NR | NR | + | NR | 9 months | 9 | 73 / 10 | Fair
Steed, 2005^85^ | MDS (total) | ≈ | NR | NR | NR | 1.25 months + booster @ 3 months | 6 | 51 / 16 | Poor
Toobert,2011^86^ | COCSC | NR | + | + | NR | 12 months | 37 | 61 / 22 | Fair
Quality of life/functional status
Adolfsson, 2007^75^ | Adapted WHO QOL | NR | NR | ≈ | NR | 7 months (max) | 5 | 53 / 13 | Fair
Khunti, 2012^68^ Davies, 2008^70^ | WHO QOL-BREF | NR | NR | NR | ≈ | 1 day or 2 half-days | 1 | NA / 11 | Good
Khunti, 2012^68^ Davies, 2008^70^ | HADS | ≈ | ≈ | + | ≈ | 1 day or 2 half-days | 1 | NA / 11 | Good
Lorig, 2009^69^ | PHQ-9 (depression) | NR | + | NR | NR | 1.5 months | 6 | NA / 15 | Fair
Rygg, 2012^21^ | SF-36 (physical) | NR | ≈ | ≈ | NR | 1.25 months | 3 | 91 / 9 | Fair
Rygg, 2012^21^ | SF-36 (mental) | NR | ≈ | ≈ | NR | 1.25 months | 3 | 91 / 9 | Fair
Rygg, 2012^21^ | EQ-5D | NR | ≈ | ≈ | NR | 1.25 months | 3 | 91 / 9 | Fair
Schillinger, 2009^30^ | SF-12 (physical) | NR | NR | ≈ | NR | 9 months | 9 | 73 / 10 | Fair
Schillinger, 2009^30^ | SF-12 (mental) | NR | NR | ≈ | NR | 9 months | 9 | 73 / 10 | Fair
Steed, 2005^85^ | ADDQOL | + | NR | NR | NR | 1.25 months + booster @ 3 months | 6 | 51 / 16 | Poor
Steed, 2005^85^ | SF-36 | ≈ | NR | NR | NR | 1.25 months + booster @ 3 months | 6 | 51 / 16 | Poor
Toobert, 2011^86^ | CDC Healthy Days (physical) | NR | ≈ | ≈ | NR | 12 months | 37 | 61 / 22 | Fair
Toobert, 2011^86^ | CDC Healthy Days (mental) | NR | ≈ | ≈ | NR | 12 months | 37 | 61 / 22 | Fair
Biophysical and performance measures ∥
Dejesus, 2009^77^ | Systolic blood pressure | NR | ≈ | NR | NR | 1 day | 1 | 13 / 55 | Poor
Utilization
Dejesus, 2009^77^ | RN and MD visits | NR | ≈ | NR | NR | 1 day | 1 | 13 / 55 | Poor
Lorig, 2009^69^ | MD visits | NR | ≈ | NR | NR | 1.5 months | 6 | NA / 15 | Fair
Lorig, 2009^69^ | ED visits | NR | ≈ | NR | NR | 1.5 months | 6 | NA / 15 | Fair
Lorig, 2009^69^ | Days hospitalized | NR | ≈ | NR | NR | 1.5 months | 6 | NA / 15 | Fair
Rygg, 2012^21^ | Clinician visits | NR | ≈ | ≈ | NR | 1.25 months | 3 | 91 / 9 | Fair

* Symbols pertain to statistical significance p<0.05: ≈ indicates no difference between arms; + indicates in favor of the GV arm; - indicates in favor of the C arm; NR = not reported.

† Defined as percent eligible for enrollment among those invited to participate.

‡ Defined as percent lost to follow-up among those randomized.

§ Both groups experienced poorer outcome change with the intervention group experiencing less of a decline.

∥ Five of the seventeen studies included for meta-analysis of mean change in HbA1c did not report quality of life, self-efficacy, or utilization outcomes.17,18,79,82,83 As a result, these studies are not represented in Table 11.

Table 14 Findings from interventions comparing group visits to usual care control for the management of chronic conditions in studies of populations with multiple disease groups

Study | Outcome measure | Findings by time period^*^ | | | | GV intervention duration | #visits | % Participation^†^/% Loss Follow-up^‡^ | Study quality
Study | Outcome measure | 0-3 mo | 4-6 mo | 7-12 mo | 13+ mo | GV intervention duration | #visits | % Participation^†^/% Loss Follow-up^‡^ | Study quality
Self-efficacy
Lorig 1999^92^ | Cognitive symptom management | NR | + | NR | NR | 7 weeks | 7 | NR / 17 | Fair
Lorig, 2003^91^ | 4-item self-efficacy scale | NR | + | + | NR | 6 weeks | 6 | NR / 51 | Fair
Fu, 2003^90^ | 4-item self-efficacy scale | NR | ≈ | NR | NR | 7 weeks | 7 | NA / 13 | Fair
Fu, 2003^90^ | Cognitive symptom scale | NR | + | NR | NR | 7 weeks | 7 | NA / 13 | Fair
Elzen, 2007^89^ | GSES-16 (Dutch) | ≈ | ≈ | NR | NR | 6 weeks | 6 | 26 / 10 | Poor
Elzen, 2007^89^ | Cognitive symptom scale | ≈ | ≈ | NR | NR | 6 weeks | 6 | 26 / 10 | Poor
Quality of life
Lorig, 1999^92^ | Self-rated health^§^ | NR | + | NR | NR | 7 weeks | 7 | NR / 17 | Fair
Lorig, 1999^92^ | Disability (HAQ) | NR | + | NR | NR | 7 weeks | 7 | NR / 17 | Fair
Elzen, 2007^89^ | RAND-36 physical and mental components | ≈ | ≈ | NR | NR | 6 weeks | 6 | 26 / 10 | Poor
Utilization
Lorig, 1999^92^ | Physician visits | NR | ≈ | NR | NR | 7 weeks | 7 | NR / 17 | Fair
Lorig, 1999^92^ | Hospital stays | NR | + | NR | NR | 7 weeks | 7 | NR / 17 | Fair
Lorig, 2003^91^ | Physician visits | NR | ≈ | ≈ | NR | 6 weeks | 6 | NR / 51 | Fair
Lorig, 2003^91^ | ER visits | NR | + | + | NR | 6 weeks | 6 | NR / 51 | Fair
Lorig, 2003^91^ | Hospital days | NR | ≈ | ≈ | NR | 6 weeks | 6 | NR / 51 | Fair
Fu, 2003^90^ | Physician visits | NR | ≈ | NR | NR | 7 weeks | 7 | NA / 13 | Fair
Fu, 2003^90^ | ER visits | NR | ≈ | NR | NR | 7 weeks | 7 | NA / 13 | Fair
Fu, 2003^90^ | Hospital days | NR | ≈ | NR | NR | 7 weeks | 7 | NA / 13 | Fair

* Symbols pertain to statistical significance p<0.05: ≈ indicates no difference between arms; + indicates in favor of the GV arm; - indicates in favor of the C arm; NR = not reported.

† Defined as percent eligible for enrollment among those invited to participate.

‡ Defined as percent lost to follow-up among those randomized.

§ National Health Interview Survey measure94

Table 16 Findings from interventions comparing group visits to control for the management of chronic pain

Study | Outcome | Findings by time period^*^ | | | | GV duration | #visits | % Participation^†^/% Loss Follow-up^‡^ | Study quality
Study | Outcome | 0-3 mo | 4-6 mo | 7-12 mo | 13+ mo | GV duration | #visits | % Participation^†^/% Loss Follow-up^‡^ | Study quality
Self-efficacy
Ersek, 2003^97^ | Survey of Pain Attitudes | ≈ | NR | NR | NR | 8 weeks | 7 | NA / 13 | Fair
Gustavsson, 2010^98^ | CSQ (pain control) | + | NR | NR | NR | 20 weeks | 8 | 84 / 20 | Good
Gustavsson, 2010^98^ | Self Efficacy Scale | ≈ | NR | NR | NR | 20 weeks | 8 | 84 / 20 | Good
Vlaeyen, 1996^96^ GV1 vs. UC | Pain coping construct | + | NR | NR | NR | 6 weeks | 12 | NR / 20 | Fair
Vlaeyen, 1996^96^ GV2 vs. UC | Pain coping construct | + | NR | NR | NR | 6 weeks | 12 | NR / 20 | Fair
Quality of life
Ersek, 2003^97^ | SF-36 (physical and physical functioning) | ≈ | NR | NR | NR | 8 weeks | 7 | NA / 13 | Fair
Ersek, 2003^97^ | Graded chronic pain scale – activity interference | ≈ | NR | NR | NR | 8 weeks | 7 | NA / 13 | Fair
Haugli, 2000 & Haugli, 2003^28,95^ | VAS (pain) | ≈ | NR | +^§^ | NR | 9 months | 12 | NA / 33 | Poor
Gustavsson, 2010^98^ | Neck Disability Index | + | NR | NR | NR | 20 weeks | 8 | 84 / 20 | Good
Utilization/Costs
Haugli, 2000 & Haugli, 2003^28,95^ | Self-reported MD visits | + | NR | +^§^ | NR | 9 months | 12 | NA / 33 | Poor

* Symbols pertain to statistical significance p<0.05: ≈ indicates no difference between arms; + indicates in favor of the GV arm; - indicates in favor of the C arm; NR = not reported.

† Defined as percent eligible for enrollment among those invited to participate.

‡ Defined as percent lost to follow-up among those randomized.

§ P-value not reported.

Figure 3 Effect of group visits compared to usual care on HbA1C at ≤6 month follow-up, by study quality

Figure 4 Effect of group visits on HbA1C compared to usual care at ≤6 month follow-up, by duration of intervention

Figure 5 Effect of group visits compared to usual care on HbA1C at 7-12 month follow-up, by study quality

Figure 6 Effect of group visits compared to usual care on HbA1C at 7-12 month follow-up, by duration of intervention

Overall, group visit interventions in most clinical areas were associated with short- and medium-term improvements in self-efficacy; few studies examining longer-term outcomes. However, there was little evidence that interventions improved quality of life, functional status, or utilization outcomes. Group visit interventions were associated with modest short-term improvements in HbA1c, but the strength of this evidence was low because of inconsistent results across studies and methodological concerns in the studies finding the greatest benefit.

### Key Question 2 For adults with chronic medical conditions, do the effects of group visits vary by patient characteristics?

Relatively few studies specifically examined how patient characteristics modified intervention effects. Sixteen studies presented results of group visit interventions by patient characteristics: nine diabetes mellitus studies,13-21 two arthritis studies,22,23 two history of falls studies,24,25 one hypertension study,26 one CHF study,27 and one chronic pain study.28

Many of these studies examined group visit effectiveness for participants who attended a greater number of sessions relative to those with greater absentee rates.13,16,18,19 Overall, the studies found some indications of a dose-response with group session attendance, with those participants attending the greatest number of sessions benefitting the most from the group visit intervention. For the DM studies, many found larger beneficial group visit intervention effects for patients with higher initial levels of HbA1c.14,17,21

Overall, studies found little difference in group visit effectiveness according to patient demographic and socioeconomic characteristics (e.g., gender, education, age, race). However, among studies of arthritis and history of falls, two studies found that obese patients tended to respond to aerobic exercise group visits more than participants with lower BMI on self-reported disability22 and falls.24 Among hypertension and CHF studies, Smeulders et al. found patients with more years of education and better cognitive status showed greater short-term improvements in cardiac-specific QoL.27 One chronic pain study noted that group visit effectiveness was modified by agency-orientation, with high agency-oriented participants experiencing improvements in pain and pain coping resulting from group visit sessions.28 Various authors note that small sample sizes limit the power to detect differences in subgroup analyses. In addition, findings of group visit benefit in subgroup analyses are tempered by fair and poor quality ratings for many of these studies.

### Key Question 3 Which components of group visits are associated with greater intervention effects?

Tables 3, 6, 9, 12, and 17 present findings of effectiveness of group visit interventions from head-to-head comparisons of multiple active group visit treatment arms, as well as studies that compared individual visits to group visits. Overall, in five studies, group visit interventions that focused on SME strategies were more effective than sessions that were limited to DE; however, in four of these five studies, the intervention arms differed considerably from the comparators (e.g., having nonequivalent number of sessions), limiting the strength of this conclusion. Studies that compared group visits to individual education visits found mixed results on a variety of outcomes, with no appreciable differences found in three studies, positive effects found with group visits in four other studies, and improvements with individual education in one study. Findings across studies could not be combined because of differences in study design. Two studies compared the effects of in-person group SME and mailed or automated self-management programs, and found no differences in self-efficacy, pain, and functional status outcomes.29,30

## Findings by Clinical Area

### Arthritis

Eighteen studies from the US, Europe, and Australia evaluated the effectiveness of educational group visit interventions that included self-management skills (eleven studies), didactic (eight studies), and experiential approaches (six studies).22,23,29,31-44 Studies varied widely in intervention structure, content, and duration, as well as comparison group (Tables 1-3).

Seven of ten studies found group visit interventions improved short- and medium-term self-efficacy; in six of the studies finding benefit the interventions focused on self-management skills education. Only one poor-quality study assessed outcomes beyond 12 months.44 Despite the improvements seen in self-efficacy, only two of eleven studies found improvements in quality of life related measures such as disability41 and depression.32 One US study found a self-management education intervention was associated with reduced physician visits,41 but this finding was not confirmed in five other studies conducted in Europe and Australia.31,32,34,35,40

Eight studies compared two active interventions (Table 3). Many of these studies were comparing interventions with more than one characteristic that differed (i.e., different educational content and different number of sessions), making it more difficult to assess which intervention components may have been associated with observed effects. One study compared a self-management to a didactic education intervention with the same number of sessions and found no difference in outcomes between them.36 Another study found that the inclusion of significant others along with patients in a self-management education intervention was actually associated with lower self-efficacy than the intervention delivered to patients alone.42 Finally, one study found similar effects from a mail-delivered individualized self-management program and an in-person group self-management education intervention.29

Overall, there is a moderately strong body of evidence that group self-management education interventions can improve short- and medium-term self-efficacy in patients with arthritis, but they have little effect on quality of life or utilization outcomes.

### History of Falls

Four studies from the US, Canada, and Australia examine effectiveness of educational group visit interventions in patients with a history of falls or at-risk for falling (Tables 1-3).24,25,45,46

Two studies found a group didactic education and exercise intervention improved self-efficacy over the short-term,45 while another study which included a “booster” education session at three months found improved long-term self-efficacy.24 One study found improved timed-up-and-go (TUG) physical performance,24 while another study found the intervention did not improve TUG when patients were simultaneously tasked with cognitive activities.25 Only one of three studies found a reduction in fall events,24 and no studies found improved quality of life.

Overall, didactic falls prevention training along with exercise training may improve patient self-efficacy and reduce the risk of falls, though the strength of this evidence is low because of inconsistencies among studies and the small number of studies.

### Asthma, COPD

Five studies conducted in the US or Australia examined the effects of group visit interventions compared with usual care in patients with asthma (Table 4).48-52 The group interventions involved didactic education in four studies49-52 and self-management education in one study.48 Decreased utilization was observed in two studies,48,51 and improvements in quality of life measures were noted in two studies.48,49 The studies were limited by selection bias and other methodological issues, however, and study quality was fair to poor.

Five studies of group visits in COPD patients were conducted in a variety of settings: Northern Ireland,53 the UK,54 the Netherlands,55 France,56 and a VA Medical Center in the US.57 Three studies compared didactic education combined with exercise training to DE alone54,55 or to usual care.56 Two other studies examined the effects of SME compared with DE,57 usual care,53 or individual support.53 The group education sessions were held weekly or biweekly for four to eight weeks, and two studies with exercise components continued the exercise sessions monthly for up to a year (Table 4).54,55 Better exercise capacity was observed in the studies that combined exercise training with DE, as compared with usual care56 or with DE alone (Tables 5 and 6).54,55 One of these was a small, good-quality study that also found the intervention improved the symptom subscale of the St. George's Respiratory Questionnaire but not activity level.56 In a smoking cessation intervention study, five weeks of SME group sessions had no effect on smoking cessation at 12 months, compared with usual care.53 A study comparing DE group visits with cognitive-behavioral therapy SME group visits among US Veterans with COPD found that both types of group visits significantly improved QOL, anxiety, depression, and 6MWD, with no significant differences between groups.57

Overall, a small body of fair-to-good quality evidence suggests that group exercise training in combination with didactic education may be associated with small improvements or less decline over time in exercise capacity and COPD symptoms, though the clinical significance of these findings is unclear. There is little methodologically sound evidence examining the impact of group visits in patients with asthma.

### Hypertension, CHF, CAD

Our literature search identified two fair-quality studies of group visit interventions conducted in patients with CHF or CAD,58,59 and one good-quality study published in two reports27,60 (Table 7). One study compared cardiac education lectures with usual care in US Veterans with moderately severe CHF, and found no difference in quality of life after 15 weeks of DE sessions.59 A study conducted in a non-Veteran US population used cognitive-behavioral change counseling to increase exercise maintenance in patients with MI, CABG or angioplasty, and found that subjects in the usual care group were significantly more likely to stop exercising in the year following completion of a cardiac rehabilitation program compared with subjects in the intervention group, although standardized self-efficacy measures indicated no differences between groups (Table 8).58 The study conducted in the Netherlands27,60 used the Chronic Disease Self-Management Program (CDSMP) developed by Lorig and colleagues for the management of multiple chronic diseases.61 The CDSMP was associated with short-term improvements in cognitive symptom management, self-care behavior, and cardiac-specific QOL among patients with CHF in the Netherlands, but no long-term effects were found.27,60

Seven studies examined the effects of group visits on blood pressure in patients with hypertension.26,62-67 The studies were conducted in a range of international settings, and study quality varied widely (Table 7). Three studies used SME techniques26,63,66 and three studies used DE62-64,67 in comparison with usual care or an informational control. One trial compared SME directly with DE (Table 9).65 Reductions in blood pressure measurements were noted in all three SME studies26,63,66 and in one DE study.62 In the trial comparing SME directly with DE, there were no significant reductions in SBP or DBP found in either group at three months. However, significantly more SME patients had controlled BP, defined as the proportion of patients with mean 24-h BP < 140/90 mm Hg, compared with DE (70% vs 44%, p=0.04).

Overall, there were very few studies of group visits in CHF patients, and their findings on self-efficacy, quality of life, and biophysical measures were largely neutral. Group self-management education interventions in patients with hypertension have reported improvements in blood pressure control in short-term and long-term studies, but the overall strength of evidence is low.

### Diabetes Mellitus

We included 30 publications of 29 studies of group visit interventions in patients with DM (Table 10). We conducted meta-analyses of the 17 studies comparing the effects of a group visit intervention to usual care on HbA1c (Figures 3-6). Overall, in 14 studies, group visit interventions reduced HbA1c slightly more over six months of follow-up than usual care, though there was significant heterogeneity which should temper confidence in these results (Figure 3, mean difference HbA1c -0.27%; 95% CI -0.44 to -0.11; I^2^=67.1%). At least part of the heterogeneity seemed to be associated with study quality. The two good quality studies found no short-term improvements in HbA1c (mean difference HbA1c 0.02; 95% CI -0.14 to 0.17; I^2^=0.0%). Group visit interventions lasting more than three months appeared to have a more pronounced effect on HbA1c improvement than those of shorter duration (-0.49% vs -0.20%), but the quality of these longer duration intervention studies was also lower (Figure 4). We found similar effects on HbA1c at 7 to 12 months in the 10 studies with longer-term follow-up (Figures 5 and 6). Funnel plot analyses showed no evidence of publication bias for 6 month outcomes (Egger bias coefficient=-1.62, 95% CI [-3.73 to 0.48]), but some evidence of publication bias for 12 month outcomes (Egger bias coefficient=-2.14, 95% CI [-3.62 to -0.66]). Multivariate meta-regression models showed that none of the covariates examined—duration of the group visit intervention, study quality, or year of publication—were independently associated with changes in HbA1c.

Five studies found improvements in self-efficacy or illness belief scores with four of these studies finding positive effects beyond six months of follow-up (Table 11). Perhaps not surprisingly, four of the five studies finding beneficial effects on self-efficacy involved interventions specifically focused on broader self-management skills training rather than didactic education.19,30,68,69

Despite finding that some interventions may improve self-efficacy, there was little evidence that group visit interventions improved quality of life over the short- or long-term (Table 11). One large, good-quality cluster-randomized trial in patients with newly diagnosed diabetes compared a six-hour self-management skills program to a control group which received equal contact time but no self-management training. Though the intervention was associated with sustained improvements in illness beliefs, there was no detectable effect on quality of life, depression or biomedical outcomes over the long-term.68,70 Few studies reported or were powered to evaluate utilization outcomes.

Eleven studies compared a group visit intervention to one or more active interventions (Table 12). Three of these studies found that interventions focused on self-management skills training were associated with greater improvements in glycemic control than didactic educational approaches, though there were multiple other differences in the interventions being compared making it difficult to draw firm conclusions about the effects of educational approach alone.14,71,72 Two studies compared group to individual education: one was a small good-quality trial which found individual education was associated with better outcomes,73 while the other was a poor-quality study showing similar effects of group and individual education.74 One fair-quality study found that an automated telephone-based self-management intervention performed similarly to an in-person group self-management skills intervention.30

Overall, we found group visit interventions in patients with diabetes may have modest effects on glycemic control over the short- and long-term, but the strength of evidence supporting this conclusion is low mostly because of inconsistencies across studies and methodological weaknesses of the studies finding the most positive effects. Interventions focused on self-management skills training were associated with improved self-efficacy and illness belief scores over the short- and long-term. However, there was no consistent evidence that group visit interventions improved quality of life.

### Multiple Chronic Conditions

Four studies evaluated the Chronic Disease Self-Management Program (CDSMP)61 in populations with various chronic conditions not limited to a particular disease group (Tables 13 and 14).89-92 The CDSMP was designed as a workshop held in community settings such as senior centers, churches, libraries and hospitals. People with different chronic health problems attend together, meeting 2.5 hours once per week for six to seven weeks. The workshops are facilitated by two trained leaders, one or both of whom are non-health professionals with chronic diseases themselves.

The largest study evaluated the CDSMP in multiple community-based sites in the US and found it was associated with improved health behaviors, including cognitive symptom management, reduced hospital utilization, and improved self-rated health and disability at six months.92 Of note, the 17 percent of patients who did not complete the study tended to have more illness related disability than those completing the trial, though there was no differential loss to follow-up between the two groups. The authors report that a full intent-to-treat analysis was conducted and that results were similar, but they fully report only the per-protocol analysis. Seventy-two percent of the wait-list control group elected to enroll in the CDSMP after the trial. A pre-post two-year follow-up study of all CDSMP participants found long-term reductions in ER and outpatient visits as well as improved self-efficacy.93 The authors estimate the cost of the program to be about $70 per participant (in 1999).

A large northern California study of the Spanish-language adaptation of the CDSMP found the intervention improved self-efficacy in the medium- and long-term, as well as decreased ER visits at 4 and 12 months.91 Another large study in China found medium-term improvements on a cognitive symptom scale, but not in self-efficacy nor on ER visits.90 Self-efficacy scales also showed mixed findings, with benefits noted in some studies but not in other studies that used the same measures (Table 14). The Dutch study was of poor-quality and found no effect of the intervention on outcomes.89

Overall, the peer-led, community-based CDSMP appears to be associated with medium-term improvements in self-efficacy, health status, and health care utilization; and these effects may persist long-term. These findings are based on moderately strong evidence from two large US trials, though findings were not replicated in other countries and the findings likely apply most to patients engaged enough in care to agree to attend a multi-week course.

### Chronic Pain

Four studies evaluated the effects of group-based interventions compared to usual care,95,96 educational reading materials,97 or individual treatment98 in patients with chronic pain (Tables 15-17). Providers for the group-based interventions varied, and included psychologists, physicians, rehabilitation specialists, nurses, physiotherapists, and physical therapists. All of the studies examined group interventions with self-management skills education components. The group-based interventions ranged from 7 to 12 sessions conducted weekly or every-other-week, and most included approximately six patients per group. Length of follow-up for the studies was generally short, approximately 0 to 3 months following completion of the group; however, two studies evaluated some outcomes up to a year following intervention completion. Though many findings from the studies were not statistically significant and did not differ from the comparison, some results favored the group-based interventions. The studies all reported results from multiple outcome measures.

Ersek and colleagues reported similar effects of a group-based intervention and educational reading materials on functional status and self-efficacy measures at three months.97 Gustavsson and colleagues (2010) reported that compared to usual individual physical therapy care, a group-based intervention had largely similar effects on multiple measures of pain control and self-efficacy, but was associated with more improvement on the Neck Disability Index and the Coping Strategies Questionnaire at 20 weeks of follow-up.98 The group visits intervention group also reported using less medication for pain at 20 weeks. One poor-quality study found group self-management education was associated with improved pain scores, reduction in psychological distress, and decreased self-reported physician visits compared to a usual care control group over 12 months. However, numerous methodological flaws including marked differences in follow-up rates between groups limit confidence in these results.28,95 Finally, a paper by Vlaeyen and colleagues (1996) describes two group-based interventions (only one including an SME component) compared to each other and to a waitlist control group.96 They report no significant differences between the group-based interventions at 6 and 12 month follow-up on almost all of the 12 outcome variables included, but report that both group-based conditions showed a benefit over waitlist control on about half of the outcomes (knowledge, pain coping, pain control, relaxation, pain behavior, and fear).

Overall, a very small body of literature suggests group-based self-management education interventions may improve pain coping skills at least over the short-term, though the strength of this evidence is low because there were few studies and the methodological quality of one of the studies finding benefit was poor.