# REFERENCES

1 Edelman D, McDuffie JR, Oddone E, Gierisch JM, Nagi A, Williams JW Jr. Shared Medical Appointments for Chronic Medical Conditions: A Systematic Review. VAESP Project #09-010. 2012.
2 Han A, Judd M, Welch V, Wu T, Tugwell P, Wells GA. Tai chi for treating rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2010;7:7.
3 Ashworth NL, Chad KE, Harrison EL, Reeder BA, Marshall SC. Home versus center based physical activity programs in older adults. Cochrane Database of Systematic Reviews. 2009;1:1.
4 Anonymous. Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998;352(9131):854-865. [pmid: 9742977].
5 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force. A review of the process. Am. J. Prev. Med. 2001;30(3S):21-35. [pmid: 11306229].
6 Guyatt G, Oxman AD, Akl EA, et al. GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J. Clin. Epidemiol. 2011;64(4):383-394. [pmid: 21195583].
7 Lorig K, Stewart A, Ritter P, González V, Laurent D, Lynch J. Outcome Measures for Health Education and other Health Care Interventions. Thousand Oaks CA. Sage Publications. 1996:24-25. 41. 45.
8 Hibbard JH, Stockard J, Mahoney ER, Tusler M. Development of the Patient Activation Measure (PAM): Conceptualizing and Measuring Activation in Patients and Consumers. Health Services Research August. 2004;39(4, Part I):1005-1026.
9 Greene J, Hibbard JH. Why Does Patient Activation Matter? An Examination of the Relationships Between Patient Activation and Health-Related Outcomes. J. Gen. Intern. Med. 2012;27(5):520-526. [pmid: 22127797].
10 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control. Clin. Trials. Sep. 1986;7(3):177-188. [pmid: 3802833].
11 Higgins JPT, Altman DG, editors. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. 2008. Version 5.0.1. The Cochrane Collaboration. 2008. Availablefrom www.cochrane-handbook.org.
12 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. Sep. 13. 1997;315(7109):629-634. [pmid: 9310563].
13 D'Eramo Melkus G, Chyun D, Vorderstrasse A, Newlin K, Jefferson V, Langerman S. The effect of a diabetes education, coping skills training, and care intervention on physiological and psychosocial outcomes in black women with type 2 diabetes. Biol Res Nurs. Jul. 2010;12(1):7-19. [pmid: 20484058].
14 Weinger K, Beverly EA, Lee Y, Sitnokov L, Ganda OP, Caballero AE. The effect of a structured behavioral intervention on poorly controlled diabetes: a randomized controlled trial. Arch. Intern. Med. Dec. 12. 2011;171(22):1990-1999. [pmid: 21986346].
15 Brown SA, Garcia AA, Kouzekanani K, Hanis CL. Culturally competent diabetes self-management education for Mexican Americans: the Starr County border health initiative. Diabetes Care. Feb. 2002;25(2):259-268. [pmid: 11815493].
16 Brown SA, Blozis SA, Kouzekanani K, Garcia AA, Winchell M, Hanis CL. Dosage effects of diabetes self-management education for Mexican Americans: the Starr County Border Health Initiative. Diabetes Care. Mar. 2005;28(3):527-532. [pmid: 15735182].
17 Hornsten A, Stenlund H, Lundman B, Sandstrom H. Improvements in HbA1c remain after 5 years--a follow up of an educational intervention focusing on patients' personal understandings of type 2 diabetes. Diabetes Res. Clin. Pract. Jul. 2008;81(1):50-55. [pmid: 18372074].
18 Philis-Tsimikas A, Fortmann A, Lleva-Ocana L, Walker C, Gallo LC. Peer-led diabetes education programs in high-risk Mexican Americans improve glycemic control compared with standard approaches: a Project Dulce promotora randomized trial. Diabetes Care. Sep. 2011;34(9):1926-1931. [pmid: 21775748].
19 Rosal MC, Ockene IS, Restrepo A, et al. Randomized trial of a literacy-sensitive, culturally tailored diabetes self-management intervention for low-income latinos: latinos en control. Diabetes Care. Apr. 2011;34(4):838-844. [pmid: 21378213].
20 Surwit RS, van Tilburg MA, Zucker N, et al. Stress management improves long-term glycemic control in type 2 diabetes. Diabetes Care. 2002;25:30-34. [pmid: 11772897].
21 Rygg LO, Rise MB, Gronning K, Steinsbekk A. Efficacy of ongoing group based diabetes self-management education for patients with type 2 diabetes mellitus. A randomised controlled trial. Patient Educ. Couns. Jan. 2012;86(1):98-105. [pmid: 21592715].
22 Ettinger WH Jr., Burns R, Messier SP, et al. A randomized trial comparing aerobic exercise and resistance exercise with a health education program in older adults with knee osteoarthritis. The Fitness Arthritis and Seniors Trial (FAST). JAMA. Jan. 1. 1997;277(1):25-31. [pmid: 8980206].
23 Hammond A, Lincoln N, Sutcliffe L. A crossover trial evaluating an educational-behavioural joint protection programme for people with rheumatoid arthritis. Patient Educ. Couns. May. 1999;37(1):19-32. [pmid: 10640116].
24 Clemson L, Cumming RG, Kendig H, Swann M, Heard R, Taylor K. The effectiveness of a community-based program for reducing the incidence of falls in the elderly: a randomized trial. J. Am. Geriatr. Soc. Sep. 2004;52(9):1487-1494. [pmid: 15341550].
25 Shumway-Cook A, Silver HF, LeMier M, York S, Cummings P, Koepsell TD. Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. Journals of Gerontology Series A: Biological Sciences & Medical Sciences. 2007;62A(12):1420-1427.
26 Svetkey LP, Pollak KI, Yancy WS Jr., et al. Hypertension improvement project: randomized trial of quality improvement for physicians and lifestyle modification for patients. Hypertension. Dec. 2009;54(6):1226-1233. [pmid: 19920081].
27 Smeulders ES, van Haastregt JC, Ambergen T, et al. Heart failure patients with a lower educational level and better cognitive status benefit most from a self-management group programme. Patient Educ. Couns. Nov. 2010;81(2):214-221. [pmid: 20153132].
28 Haugli L, Steen E, Laerum E, Finset A, Nygaard R. Agency orientation and chronic musculoskeletal pain: effects of a group learning program based on the personal construct theory. Clin. J. Pain. Dec. 2000;16(4):281-289. [pmid: 11153782].
29 Lorig KR, Ritter PL, Laurent DD, Fries JF. Long-term randomized controlled trials of tailored-print and small-group arthritis self-management interventions. Med. Care. Apr. 2004;42(4):346-354. [pmid: 15076811].
30 Schillinger D, Handley M, Wang F, Hammer H. Effects of self-management support on structure, process, and outcomes among vulnerable patients with diabetes: a three-arm practical clinical trial. Diabetes Care. Apr. 2009;32(4):559-566. [pmid: 19131469].
31 Ackerman IN, Buchbinder R, Osborne RH. Challenges in Evaluating an Arthritis Self-management Program for People with Hip and Knee Osteoarthritis in Real-world Clinical Settings. The Journal of Rheumatology. 2012;39(5):1-9. [pmid: 22210674].
32 Barlow JH, Turner AP, Wright CC. A randomized controlled study of the Arthritis Self-Management Programme in the UK. Health Educ. Res. Dec. 2000;15(6):665-680. [pmid: 11142075].
33 Breedland I, van Scheppingen C, Leijsma M, Verheij-Jansen NP, van Weert E. Effects of a group-based exercise and educational program on physical performance and disease self-management in rheumatoid arthritis: a randomized controlled study. Phys. Ther. Jun. 2011;91(6):879-893. [pmid: 21474637].
34 Buszewicz M, Rait G, Griffin M, et al. Self management of arthritis in primary care: randomised controlled trial. BMJ (Clinical research ed.). Oct. 2006;333(7574):879.
35 Patel A, Buszewicz M, Beecham J, et al. Economic evaluation of arthritis self management in primary care. BMJ. 2009;339:b3532. [pmid: 19773329].
36 Freeman K, Hammond A, Lincoln NB. Use of cognitive-behavioural arthritis education programmes in newly diagnosed rheumatoid arthritis. Clin. Rehabil. Dec. 2002;16(8):828-836. [pmid: 12501944].
37 Giraudet-Le Quintrec J, Mayoux-Benhamou A, Ravaud P, et al. Effect of a collective educational program for patients with rheumatoid arthritis: a prospective 12-month randomized controlled trial. J. Rheumatol. 2007;34(8):1684-1691. [pmid: 17610321].
38 Hewlett S, Ambler N, Almeida C, et al. Self-management of fatigue in rheumatoid arthritis: a randomised controlled trial of group cognitive-behavioural therapy. Ann. Rheum. Dis. Jun. 2011;70(6):1060-1067. [pmid: 21540202].
39 Kaplan S, Kozin F. A controlled study of group counseling in rheumatoid arthritis. J. Rheumatol. Jan-Feb. 1981;8(1):91-99. [pmid: 7012343].
40 Lorig K, Lubeck D, Kraines RG, Seleznick M, Holman HR. Outcomes of self-help education for patients with arthritis. Arthritis Rheum. Jun. 1985;28(6):680-685. [pmid: 4004977].
41 Lorig K, Gonzalez VM, Ritter P. Community-based Spanish language arthritis education program: a randomized trial. Med. Care. Sep. 1999;37(9):957-963. [pmid: 10493473].
42 Riemsma RP, Taal E, Rasker JJ. Group education for patients with rheumatoid arthritis and their partners. Arthritis Rheum. Aug. 15. 2003;49(4):556-566. [pmid: 12910564].
43 Sevick MA, Miller GD, Loeser RF, Williamson JD, Messier SP. Cost-effectiveness of exercise and diet in overweight and obese adults with knee osteoarthritis. Med. Sci. Sports Exerc. 2009;41(6):1167-1174. [pmid: 19461553].
44 Taal E, Riemsma RP, Brus HL, Seydel ER, Rasker JJ, Wiegman O. Group education for patients with rheumatoid arthritis. Patient Educ. Couns. May. 1993;20(2-3):177-187. [pmid: 8337194].
45 Arnold CM, Faulkner RA. The effect of aquatic exercise and education on lowering fall risk in older adults with hip osteoarthritis. J Aging Phys Act. Jul. 2010;18(3):245-260. [pmid: 20651413].
46 Ryan JW, Spellbring AM. Implementing strategies to decrease risk of falls in older women. J. Gerontol. Nurs. Dec. 1996;22(12):25-31. [pmid: 9060344].
47 Hammond A, Bryan J, Hardy A. Effects of a modular behavioural arthritis education programme: a pragmatic parallel-group randomized controlled trial. Rheumatology (Oxford). Nov. 2008;47(11):1712-1718. [pmid: 18815153].
48 Wilson SR, Scamagas P, German DF, et al. A controlled trial of two forms of self-management education for adults with asthma. The American journal of medicine. Jun. 1993;94(6):564-576. [pmid: 8506881].
49 Abdulwadud O, Abramson M, Forbes A, James A, Walters EH. Evaluation of a randomised controlled trial of adult asthma education in a hospital setting. Thorax. Jun. 1999;54(6):493-500. [pmid: 10335002].
50 Allen RM, Jones MP, Oldenburg B. Randomised trial of an asthma self-management programme for adults. Thorax. Jul. 1995;50(7):731-738. [pmid: 7570406].
51 Bolton MB, Tilley BC, Kuder J, Reeves T, Schultz LR. The cost and effectiveness of an education program for adults who have asthma. J. Gen. Intern. Med. Sep-Oct. 1991;6(5):401-407. [pmid: 1744753].
52 Snyder SE, Winder JA, Creer TJ. Development and evaluation of an adult asthma self-management program: Wheezers Anonymous. J. Asthma. 1987;24(3):153-158. [pmid: 3505528].
53 Wilson JS, Fitzsimons D, Bradbury I, Stuart Elborn J. Does additional support by nurses enhance the effect of a brief smoking cessation intervention in people with moderate to severe chronic obstructive pulmonary disease? A randomised controlled trial. Int. J. Nurs. Stud. Apr. 2008;45(4):508-517. [pmid: 17184783].
54 Bestall JC, Paul EA, Garrod R, Garnham R, Jones RW, Wedzicha AJ. Longitudinal trends in exercise capacity and health status after pulmonary rehabilitation in patients with COPD. Respir. Med. Feb. 2003;97(2):173-180. [pmid: 12587969].
55 Effing T, Zielhuis G, Kerstjens H, van der Valk P, van der Palen J. Community based physiotherapeutic exercise in COPD self-management: a randomised controlled trial. Respir. Med. Mar. 2011;105(3):418-426. [pmid: 20951018].
56 Ninot G, Moullec G, Picot MC, et al. Cost-saving effect of supervised exercise associated to COPD self-management education program. Respir. Med. Mar. 2011;105(3):377-385. [pmid: 21036024].
57 Kunik ME, Veazey C, Cully JA, et al. COPD education and cognitive behavioral therapy group treatment for clinically significant symptoms of depression and anxiety in COPD patients: a randomized controlled trial. Psychol. Med. Mar. 2008;38(3):385-396. [pmid: 17922939].
58 Moore SM, Charvat JM, Gordon NH, et al. Effects of a CHANGE intervention to increase exercise maintenance following cardiac events. nn. Behav. Med. 2006;31(1):53-62.
59 Chang BH, Hendricks A, Zhao Y, Rothendler JA, LoCastro JS, Slawsky MT. A relaxation response randomized trial on patients with chronic heart failure. J Cardiopulm Rehabil. May-Jun. 2005;25(3):149-157. [pmid: 15931018].
60 Smeulders ES, van Haastregt JC, Ambergen T, et al. Nurse-led self-management group programme for patients with congestive heart failure: randomized controlled trial. J. Adv. Nurs. Jul. 2010;66(7):1487-1499. [pmid: 20492026].
61 Stanford School of Medicine. Chronic Disease Self-Management Program. http://patienteducation.stanford.edu/programs/cdsmp.html. Sept 20 2012.
62 Nessman DG, Carnahan JE, Nugent CA. Increasing compliance. Patient-operated hypertension groups. Arch. Intern. Med. Nov. 1980;140(11):1427-1430. [pmid: 7436639].
63 Rujiwatthanakorn D, Panpakdee O, Malathum P, Tanomsup S. Effectiveness of a self-management program for Thais with essential hypertension. Pacific Rim International Journal of Nursing Research. 2011;15(2):97-109.
64 Balcazar HG, Byrd TL, Ortiz M, Tondapu SR, Chavez M. A randomized community intervention to improve hypertension control among Mexican Americans: using the promotoras de salud community outreach model. J. Health Care Poor Underserved. Nov. 2009;20(4):1079-1094. [pmid: 20168020].
65 Figar S, Galarza C, Petrlik E, et al. Effect of education on blood pressure control in elderly persons: a randomized controlled trial. Am. J. Hypertens. Jul. 2006;19(7):737-743. [pmid: 16814130].
66 Scala D, D'Avino M, Cozzolino S, et al. Promotion of behavioural change in people with hypertension: an intervention study. Pharm. World Sci. Dec. 2008;30(6):834-839. [pmid: 18584303].
67 Baghianimoghadam MH, Rahaee Z, Morowatisharifabad MA, Sharifirad G, Andishmand A, Azadbakht L. Effects of education on self-monitoring of blood pressure based on BASNEF model in hypertensive patients. JRMS. 2010;15(2):70-77. [pmid: 21526062].
68 Khunti K, Gray LJ, Skinner T, et al. Effectiveness of a diabetes education and self management programme (DESMOND) for people with newly diagnosed type 2 diabetes mellitus: three year follow-up of a cluster randomised controlled trial in primary care. BMJ. 2012;344(e2333).
69 Lorig K, Ritter PL, Villa FJ, Armas J. Community-based peer-led diabetes self-management: a randomized trial. Diabetes Educ. Jul-Aug. 2009;35(4):641-651. [pmid: 19407333].
70 Davies MJ, Heller S, Skinner TC, et al. Effectiveness of the diabetes education and self management for ongoing and newly diagnosed (DESMOND) programme for people with newly diagnosed type 2 diabetes: cluster randomised controlled trial. BMJ. Mar. 1. 2008;336(7642):491-495. [pmid: 18276664].
71 Deakin TA, Cade JE, Williams R, Greenwood DC. Structured patient education: the diabetes X-PERT Programme makes a difference. Diabet Med. 08. 23. ed2006. 2006;23:944-954. [pmid: 16922700].
72 Kulzer B, Hermanns N, Reinecker H, Haak T. Effects of self-management training in Type 2 diabetes: a randomized, prospective trial. Diabet. Med. Apr. 2007;24(4):415-423. [pmid: 17298590].
73 De Greef K, Deforche B, Tudor-Locke C, De Bourdeaudhuij I. Increasing physical activity in Belgian type 2 diabetes patients: a three-arm randomized controlled trial. Int J Behav Med. 11. 06. ed2011. 2010;18:188-198. [pmid: 21052886].
74 Rickheim PL, Weaver TW, Flader JL, Kendall DM. Assessment of group versus individual diabetes education: a randomized study. Diabetes Care. 01. 30. ed2002. 2002;25:269-274. [pmid: 11815494].
75 Adolfsson ET, Walker-Engstrom ML, Smide B, Wikblad K. Patient education in type 2 diabetes: a randomized controlled 1-year follow-up study. Diabetes Res. Clin. Pract. Jun. 2007;76(3):341-350. [pmid: 17069923].
76 Anderson RM, Funnell MM, Nwankwo R, Gillard ML, Oh M, Fitzgerald JT. Evaluating a problem-based empowerment program for African Americans with diabetes: results of a randomized controlled trial. Ethn. Dis. Autumn. 2005;15(4):671-678. [pmid: 16259492].
77 Dejesus RS, Chaudhry R, Leutink DJ, Hinton MA, Cha SS, Stroebel RJ. Effects of efforts to intensify management on blood pressure control among patients with type 2 diabetes mellitus and hypertension: a pilot study. Vasc Health Risk Manag. 2009;5:705-711. [pmid: 19756162].
78 Lujan J, Ostwald SK, Ortiz M. Promotora diabetes intervention for Mexican Americans. Diabetes Educ. Jul-Aug. 2007;33(4):660-670. [pmid: 17684167].
79 Miller CK, Edwards L, Kissling G, Sanville L. Nutrition education improves metabolic outcomes among older adults with diabetes mellitus: results from a randomized controlled trial. Preventive Medicine. 2002;34:252-259. [pmid: 11817922].
80 Raji A, Gomes H, Beard JO, MacDonald P, Conlin PR. A randomized trial comparing intensive and passive education in patients with diabetes mellitus. Arch. Intern. Med. Jun. 10. 2002;162(11):1301-1304. [pmid: 12038949].
81 Sarkadi A, Rosenqvist U. Experience-based group education in Type 2 diabetes: a randomised controlled trial. Patient Educ. Couns. Jun. 2004;53(3):291-298. [pmid: 15186866].
82 Scain SF, Friedman R, Gross JL. A structured educational program improves metabolic control in patients with type 2 diabetes: a randomized controlled trial. Diabetes Educ. Jul-Aug. 2009;35(4):603-611. [pmid: 19451553].
83 Sharifirad G, Najimi A, Hassanzadeh A, Azadbakht L. Does nutrition education improve the risk factors of cardiovascular diseases among elderly with type 2 diabetes? A randomized controlled trial based on an educational model. J Diabetes. Apr. 28. 2012.
84 Sperl-Hillen J, Beaton S, Fernandes O, et al. Comparative effectiveness of patient education methods for type 2 diabetes: a randomized controlled trial. Arch. Intern. Med. Dec. 12. 2011;171(22):2001-2010. [pmid: 21986350].
85 Steed L, Lankester J, Barnard M, Earle K, Hurel S, Newman S. Evaluation of the UCL diabetes self-management programme (UCL-DSMP): a randomized controlled trial. J Health Psychol. Mar. 2005;10(2):261-276. [pmid: 15723895].
86 Toobert DJ, Strycker LA, Barrera M Jr., Osuna D, King DK, Glasgow RE. Outcomes from a multiple risk factor diabetes self-management trial for Latinas: inverted exclamation markViva Bien!. nn. Behav. Med. Jun. 2011;41(3):310-323.
87 Toobert DJ, Strycker LA, King DK, Barrera M Jr., Osuna D, Glasgow RE. Long-term outcomes from a multiple-risk-factor diabetes trial for Latinas: inverted exclamation markViva Bien!. Transl Behav Med. Sep. 2011;1(3):416-426. [pmid: 22022345].
88 Zapotoczky H, Semlitsch B, Herzog G, et al. A controlled study of weight reduction in type 2 diabetics treated by two reinforcers. International Journal of Behavioral Medicine. 2001;8(1):42-49.
89 Elzen H, Slaets JP, Snijders TA, Steverink N. Evaluation of the chronic disease self-management program (CDSMP) among chronically ill older people in the Netherlands. Soc. Sci. Med. May. 2007;64(9):1832-1841. [pmid: 17355901].
90 Fu D, Fu H, McGowan P, et al. Implementation and quantitative evaluation of chronic disease self-management programme in Shanghai, China: randomized controlled trial. Bull. World Health Organ. 2003;81(3):174-182. [pmid: 12764513].
91 Lorig KR, Ritter PL, Gonzalez VM. Hispanic Chronic Disease Self-Management: A Randomized Community-Based Outcome Trial. Nurs. Res. Nov-Dec. 2003;52(6):361-369. [pmid: 14639082].
92 Lorig KR, Sobel DS, Stewart AL, et al. Evidence Suggesting That a Chronic Disease Self-Management Program Can Improve Health Status While Reducing Hospitalization: A Randomized Trial. Medical Care January. 1999;37(1):5-14.
93 Lorig KR, Ritter PP, Stewart AL, et al. Chronic Disease Self-Management Program: 2-Year Health Status and Health Care Utilization Outcomes. Medical Care November. 2001;39(11):1217-1223.
94 US Department of Commerce. National Health Interview Survey. Bureau of the Census. 1985.
95 Haugli L, Steen E, Laerum E, Nygard R, Finset A. Psychological distress and employment status. Effects of a group learning programme for patients with chronic musculoskeletal pain. Psychology, Health & Medicine. May. 2003;8(2):135-148.
96 Vlaeyen JW, Teeken-Gruben NJ, Goossens ME, et al. Cognitive-educational treatment of fibromyalgia: a randomized clinical trial. I. Clinical effects. J. Rheumatol. Jul. 1996;23(7):1237-1245. [pmid: 8823699].
97 Ersek M, Turner JA, McCurry SM, Gibbons L, Kraybill BM. Efficacy of a self-management group intervention for elderly persons with chronic pain. Clin. J. Pain. May-Jun. 2003;19(3):156-167. [pmid: 12792554].
98 Gustavsson C, Denison E, von Koch L. Self-management of persistent neck pain: A randomized controlled trial of a multi-component group intervention in primary health care. European Journal of Pain. Jul. 2010;14(6):e1-e11. [pmid: 19939717].
99 Griffin SJ, Borch-Johnsen K, Davies MJ, et al. Effect of early intensive multifactorial therapy on 5-year cardiovascular outcomes in individuals with type 2 diabetes detected by screening (ADDITION-Europe): a cluster-randomised trial. Lancet. 9786. 378(9786):156-167. [pmid: 21705063].
100 Appel LJ, Champagne CM, Harsha DW, et al. Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. Apr. 23-30. 2003;289(16):2083-2093. [pmid: 12709466].
101 Kritikos V, Armour CL, Bosnic-Anticevich SZ. Interactive small-group asthma education in the community pharmacy setting: a pilot study. J. Asthma. Jan-Feb. 2007;44(1):57-64. [pmid: 17365206].
102 Donesky-Cuenco D, Nguyen HQ, Paul S, Carrieri-Kohlman V. Yoga therapy decreases dyspnea-related distress and improves functional performance in people with chronic obstructive pulmonary disease: a pilot study. J. Altern. Complement. Med. Mar. 2009;15(3):225-234. [pmid: 19249998].
103 Smeulders ES, van Haastregt JC, Ambergen T, Janssen-Boyne JJ, van Eijk JT, Kempen GI. The impact of a self-management group programme on health behaviour and healthcare utilization among congestive heart failure patients. Eur J Heart Fail. Jun. 2009;11(6):609-616. [pmid: 19359326].
104 Andryukhin A, Frolova E, Vaes B, Degryse J. The impact of a nurse-led care programme on events and physical and psychosocial parameters in patients with heart failure with preserved ejection fraction: a randomized clinical trial in primary care in Russia. Eur J Gen Pract. Dec. 2010;16(4):205-214. [pmid: 21073267].
105 Burke V, Mansour J, Beilin LJ, Mori TA. Long-term follow-up of participants in a health promotion program for treated hypertensives (ADAPT). Nutr Metab Cardiovasc Dis. Mar. 2008;18(3):198-206. [pmid: 17327140].
106 Pierce JP, Watson DS, Knights S, Gliddon T, Williams S, Watson R. A controlled trial of health education in the physician's office. Prev. Med. Mar. 1984;13(2):185-194. [pmid: 6377291].
107 Arnold CM. Fall risk in older adults with hip osteoarthritis: Decreasing risk through education and aquatic exercise. University of Saskatchewan (Canada). 2008.