# METHODS

## TOPIC DEVELOPMENT

The review was commissioned by the Department of Veterans Affairs' Evidence-based Synthesis Program. We conferred with VA experts to refine selection of patient populations and subgroups, interventions, outcomes, and setting addressed in the review. The current review focuses on studies involving education-based group visits interventions led by facilitators that include non-prescribing health professionals.

We addressed the following key questions in our review of the literature:

Key Question 1. In adults with chronic medical conditions, how do group visits compared to usual care affect the following:

1. medication adherence, biophysical markers ( e.g., HbA1c, blood pressure)
2. symptom status, functional status, mortality, patient satisfaction
3. utilization of medical resources, health care costs
4. adverse outcomes (e.g., patient confidentiality, participation/missed appointments)?

Key Question 2. For adults with chronic medical conditions, do the effects of group visits vary by patient characteristics? Characteristics of interest include medical diagnosis, severity of disease, and comorbidities.

Key Question 3. (Depending on the size and comparability of elements identified in the literature) Which components of group visits are associated with greater intervention effects?

The criteria for patient population, treatment and comparator interventions, outcomes of interest, and patient care setting are outlined below:

- Patients: Diagnosed with DM, HTN, CHF, COPD, asthma, arthritis, pain management, history of falls. Exclude comorbid serious mental illness such as schizophrenia. Studies with patients who have comorbid depression may be included.
- Intervention: Group visits focusing on education that are led by individuals who are non-prescribing health professionals as well as lay facilitators (e.g., dietitians, nurses, social workers, peer educators, psychologists, pulmonary technicians, physical therapists, occupational therapists). Group visits may include prescribing providers (e.g., physicians, pharmacists, advanced practice nurses, physician assistants) if they function in an advisory capacity only (i.e., do not provide individual care plans or medication management).
- Comparator: Usual care, non-group visit care
- Outcome: Biophysical/physiological (e.g., HbA1c, blood pressure) control of these markers/measures, rehospitalizations, medication adherence, ED visits, functional status, patient satisfaction, patient participation, and attrition rates.
- Timing: Any
- Setting: Any

Figure 1 illustrates the analytic framework that guided our review and synthesis.

Figure 1 Analytic framework to evaluate group visits

* Includes: gender, race/ethnicity, age, education/health literacy, rurality/geography, chronic conditions/morbidity, and other patient demographics. Note: socioeconomic influences such as financial strain (e.g., price of gas) directly affect patient participation

## SEARCH STRATEGY

We conducted searches of multiple databases [MEDLINE^®^ (PubMed^®^), Embase^®^ (Embase.com), Cochrane Register of Controlled Trials (Ovid), CINAHL (EBSCO) and PsycINFO (Ovid)] from database inception to February 2012 using terms for non-prescribing practitioners and group visit interventions, including but not limited to terms for group education, group program(me), group session(s). See Appendix A for the full search strategy. We obtained additional articles from systematic reviews, reference lists of pertinent studies, editorials, and by consulting experts.

## STUDY SELECTION

Reviewers trained in the critical analysis of literature assessed the titles and abstracts for relevance. Two investigators (AQ, JR, MF, MO, or DK) independently evaluated English-language articles included at the abstract stage using prespecified inclusion criteria (Appendix B). We included studies of group visit educational interventions led by non-prescribing facilitators. We excluded group visit studies if any portion of the intervention focused on individual-level prescription changes (e.g., blood pressure medication or insulin titration). We did not examine studies that focused exclusively on support groups or on group exercise classes (e.g., yoga, aerobic exercise, resistance training) without incorporating disease-pertinent educational components or comparing these interventions to group educational sessions. Existing Cochrane reviews of group exercise summarize the effectiveness of these interventions and represent a systematic evaluation of that literature.2,3 We excluded diabetes mellitus studies published before 1998 because we felt the overall approach to adult diabetes care was likely to have changed substantially after publication of the United Kingdom Prospective Diabetes Study, thereby rendering older studies less directly applicable today.4

## DATA ABSTRACTION

We abstracted data on the design, objectives, setting, population, demographics, findings, structure of the intervention, information on the comparator(s), and participation and attrition rates that characterized included studies. We also abstracted information on the content delivered in the group visit interventions. We distinguished between group visits whose content was to provide didactic-only educational sessions, and those that provided participants with information and training on techniques to improve coping and self-management skills. We defined the following, and abstracted this information from included studies:

- Self-management education (SME): In addition to providing disease-specific information to patients, these programs teach patients self-management skills to manage/cope with symptoms, such as goal-setting and contracting, and building skills to reinterpret symptoms (e.g., motivational interviewing, goal-setting/contracting, cognitive behavioral therapy (CBT))
- Didactic education (DE): Content is informational and format is usually lecture-based (e.g., information on the pathophysiology of disease, symptoms, using and reading equipment, potential strategies for reducing pain and stress, understanding nutritional advice)
- Experiential education (EE): Instruction based on demonstrations (e.g., exercise, cooking, reading nutritional labels and calculating nutritional information)

## STUDY QUALITY

Two reviewers independently assessed the quality of each trial according to the following criteria: randomization, allocation concealment, blinding and outcome reporting, as well as considerations for similarity of compared groups at baseline, adequate reporting of participation, loss to follow-up and attrition, the use of intention-to-treat analysis; and ascertainment of outcomes.5 Individual studies were rated as “good,” “fair,” or “poor”; these terms are defined in Appendix C.

## RATING THE BODY OF EVIDENCE

We describe the overall quality of evidence for outcomes in each clinical subsection using a method developed by the GRADE Working Group.6 The GRADE method considers the consistency, coherence, and applicability of a body of evidence, as well as the internal validity of individual studies, to classify the grade of evidence across outcomes as follows:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

## DATA SYNTHESIS

During an initial informal review of included studies, we recognized that there was a breadth of outcome categories examined, marked variation in outcome metric validity, and a large number of different outcomes measured and reported across studies. We anticipated such challenges would render a full accounting and synthesis of all outcomes both infeasible and uninformative. We chose, therefore, to focus on distal health outcomes measuring quality of life and functional status because these are likely to be important to patients and could conceivably be impacted by the interventions examined in the studies under consideration. We included utilization outcomes when reported, though we anticipated that fewer studies would be powered to examine these outcomes. We also examined intermediate outcome metrics, focusing specifically on biophysical markers such as hemoglobin A1c, and on self-efficacy or patient activation measures. Self-efficacy refers to personal beliefs in one's ability to succeed in self-managing illness. In this report, we used the term broadly and used it to refer to any measures examining self-efficacy, patient activation, coping skills, or illness beliefs. We chose to examine this group of outcomes because there are validated tools to assess self-efficacy related concepts,7,8 and these metrics were commonly reported in many studies. Furthermore, there is a link, both conceptually and empirically, between the knowledge, skills, and attitude changes one might acquire during an educational intervention and intermediate health outcomes.9

In compiling data tables, we prioritized well-validated scales and if studies report findings for full scales as well as subscales, we report full scales only. If studies did not report any outcome in these categories, or report ad-hoc/non-validated measures, their findings were summarized narratively. We also described common characteristics and themes that emerged across studies and disease categories.

We conducted meta-analyses of group visit trials for patients with diabetes for the mean difference in the change of HbA1c because we identified HbA1c as a clinically important marker for diabetes patients and one that is plausibly amenable to change in the short (0-3 months) and medium (4-6 months) term. We abstracted the mean difference and an indicator for variability (e.g., standard error) in HbA1c, and total subjects from each treatment arm. We obtained a pooled estimate of relative risk (RR) using a random effects model.10 To determine whether the effects of group visits were modified by intervention characteristics, we conducted subanalyses according to study quality, and duration of the group visit intervention.

Statistical heterogeneity was assessed by Cochran's Q test and I^2^ statistic.11 In order to examine publication bias, we used funnel plots and Egger's test to assess small study effects.12 We also conducted multivariate meta-regression analyses to determine whether duration of intervention, study quality, or publication year had any bearing on meta-analytic results. All analyses were performed using Stata 10.0 (StataCorp, College Station, TX, 2007).

## PEER REVIEW

A draft version of this report was sent to the technical expert panel and additional peer reviewers. Appendix D details the feedback we received and our responses to reviewer comments.