# INTRODUCTION

The goal of group-based educational programs led by non-prescribing practitioners is to communicate information and provide training in order to improve self-management skills for the large numbers of patients coping with chronic illness. The Veterans Administration (VA) has prioritized group visit implementation as part of a new primary care model that focuses on patient centeredness, The Patient Aligned Care Team (PACT), but the choice of which patient populations to target and which interventions to use is unclear. Though the group visit intervention delivery model has been widely used there are vast differences in program structure, content, length of intervention, and follow-up time points. Moreover, there is little consensus as to whether, and for whom, group visits are an effective tool. Given the variety of interventions, the broad array of chronic conditions in which group visit interventions have been studied, and the lack of an overall understanding of effectiveness, it is useful to clarify what is known and not known about group visit interventions in patients with chronic illness. To our knowledge, no recent review has examined group visit interventions across a variety of conditions.

The objectives of this review are to: 1) summarize the characteristics of group visit interventions that have been tested in controlled trials of patients with chronic illness; 2) assess the effects of these interventions on quality of life, self-efficacy, health care utilization, and other health outcomes; 3) understand whether there are certain patient characteristics associated with intervention effectiveness; and 4) examine which components of group visit intervention structure and delivery may be associated with intervention effects. This review serves as a companion piece to the recently published shared medical appointments review conducted by the Durham Evidence-based Synthesis Program.1 The shared medical appointments review focuses on visits led by a physician or other prescribing provider during which individual-level changes in management plan can be made. This review, in contrast, focuses exclusively on literature that tests the effectiveness of group visits that have an emphasis on health education and are led by facilitators, including but not limited to non-prescribing health professionals such as nurses, dietitians, and physical therapists.