# DISCUSSION

We found 79 trials examining the effects of group visit interventions across a variety of chronic illnesses. Despite the large evidence base, it is difficult to draw overall conclusions about the effectiveness of group visit interventions in patients with chronic illness in part because of the diversity of patient populations studied, interventions tested and outcomes reported. Nevertheless, in general, many group visit interventions appear to be able to improve short- and medium-term patient self-efficacy, but there was little consistent, fair-to-good quality evidence that they improved quality of life, health outcomes, or health care utilization. We found that diabetes group visit interventions were likely associated with small short-term improvements in glycemic control. The longer-term effects of group visit interventions are largely unknown since the vast majority of studies focused on short-term effects.

As the description of studies in our review suggests, educating patients with chronic illness is a highly complex endeavor with interventions varying in their intended purpose, content delivered, leadership, intensity, format and more. Studies comparing two or more active interventions can begin to help elucidate whether or not there are certain intervention factors associated with better outcomes. There were few studies directly comparing a purely didactic, informational education approach to one focused on core self-management skills, though, not surprisingly, most studies finding improvements in self-efficacy focused on the latter. Group and individual approaches to education appear to have similar effects. Other comparisons are summarized in the tables above, but there were not enough studies to draw conclusions about the effects of other intervention elements.

Learning and mastering chronic illness self-management is a time-consuming process. Theoretically, one might reasonably expect the duration of an intervention to be associated with its effectiveness, but we found it difficult to confirm this hypothesis. For example, we did find greater improvement in glycemic control among those interventions lasting longer than 3 months compared to interventions of shorter duration. However, the interventions of longer duration were also of lower methodological quality. Unfortunately, we found few studies examining the effects of a “booster” session (i.e., a refresher session conducted some time after the initial intervention ended).

It is unclear why the group visit interventions literature has not found a consistent impact on health, utilization, or quality of life outcomes despite the logical inference that improved self-efficacy and self-management skills should lead to improved self-management, improved disease control and coping, and resultant improved outcomes. It is possible that intervention or follow-up duration has been inadequate as discussed above. It is also possible that - in an era promoting guideline dissemination, electronic health records, and quality improvement - it is becoming increasingly difficult to demonstrate incremental benefits of an educational intervention because usual care has improved over time. Indeed, a recent trial of intensive diabetes treatment found few health outcome effects in part, as the authors speculate, because treatment in the usual care group was quite good.99

We found no formal cost-effectiveness data to guide decision-making about the wisdom of widespread investment in group visit education modalities. However, one can easily infer that there is likely to be great variation in costs of different interventions depending on the personnel leading the visits, the duration of the intervention, and the number of visits. For example, some interventions – such as cognitive behavioral therapy – are fairly intensive and would involve allocating a professional's time. Many of the self-management skills training interventions improved self-efficacy but not health outcomes. Whether group visit expenditures are warranted may depend on how highly more proximate outcome measures like self-efficacy are valued by patients and the health system.

On the other hand, peer-led, community-based self-management programs – such as the CDSMP – may represent a low-cost way of improving self-efficacy and perhaps improving other outcomes. However, such programs do not provide some of the core skills and information patients with a given chronic illness might need to help self-manage their illness (e.g., glucose self-monitoring, dietary plans, CHF management plans). It is not clear from most studies how this core information was provided. If VA were to implement such peer-led self-management programs, it would likely still need a structure for providing basic disease-specific informational needs, though this could be accomplished in different ways including single group visit, educational pamphlets, etc. It is also not clear how much the community-based nature of the intervention matters. Offering the programs in local churches, and community centers may make it easier for patients to participate on an ongoing basis and perhaps may provide a less threatening environment. It would be useful to use qualitative and formative evaluation methods if implementation of such programs were considered, in order to shed more light on such issues.

Although we did not find direct harms associated with group visits, the lack of robust findings that group visits improve long-term health outcomes invites caution around blanket recommendations for widespread and rapid group visit implementation. This is especially true for patient populations with specific health needs. For instance, travel and participation time involved in getting to and participating in group visits may preclude participation for patients with limited work schedule flexibility, and may be prohibitive for frail, older participants.

Of note, we excluded studies focused on experiential exercise (i.e., group exercise classes) without a distinct educational component, so we cannot comment on their effectiveness. Other reviews may provide more information on the utility of experiential exercise sessions.2,3 We found few studies examining the incremental benefits of experiential exercise added to group education, so were unable to draw conclusions about the utility of such interventions.

## GENERALIZABILITY

Participation rates, when reported, ranged from 13 to 100 percent though many studies provided little information about the recruitment process. The broad range of participation, in part, reflects the many levels of potential eligibility, and the higher rates may be misleading. For instance, in one study, over 21,000 patients were identified in an administrative database.57 Only one-third of these patients were successfully contacted by letter, only one-quarter of who were screened by phone, and then only a small portion of these patients attended in-person screening. Though 91 percent of those eligible at this stage were randomized, only one percent of patients identified through the administrative database actually enrolled in the study. In practical terms, these studies generally represent a small fraction of the total number of patients with chronic illness and, therefore, will apply to relatively few people identified through patient registries. Findings from the studies included in this review are likely to be most applicable to those patients who are easy to contact, have time to participate in an intervention, and who have enough motivation to enter into a study in the first place.

We identified four studies that examined group visit interventions in Veteran populations, one each in hypertensive,62 congestive heart failure,59 chronic obstructive pulmonary disease,57 and diabetes populations.80 These studies investigated interventions that were similar to other interventions tested in non-Veteran populations. We found no studies evaluating interventions that were specific to a given setting (e.g., tied to a specific technology unavailable in VA) or that would not be potentially feasible in a VA setting.

## LIMITATIONS

In setting out to perform this systematic review of group visit interventions led by non-prescribing facilitators, a chief limitation is comparability of studies given the vast heterogeneity and complexity of intervention content and outcomes examined. Although there have been many published studies testing group visit effectiveness, we found few with similar enough characteristics to be explicitly compared in meta-analyses. The sheer number and variety of outcomes reported across studies precluded reporting of all outcomes. We prespecified those outcomes that were either likely to be commonly reported, represented clinically important outcomes, or measured self-efficacy since this was, in many cases, the intended effect of the intervention. We acknowledge, however, that there may be other important outcomes not captured in this report. Most notably, we did not consider knowledge improvement outcomes. Many studies reported various knowledge outcomes, but few were standardized and they varied so broadly that any comparison across studies would have been impossible. Moreover, one could argue the clinical importance of short-term knowledge gains if they do not translate into gains in self-efficacy, health outcomes, or quality of life. Additionally, we found good quality trials testing the effectiveness of multicomponent interventions that included both, group and individual elements.100 Unfortunately, these trials were not included in our review because the independent effects of the group visit component could not be evaluated.

## FUTURE RESEARCH

We identify gaps in evidence of the effectiveness of group visit interventions in Table 18.

Table 18 Evidence gaps and future research

Evidence Gap | Recommendations / Types of studies to consider
Patients/Populations
Low participation of eligible study participants and high attrition of randomized participants. Few good quality studies in patients with asthma, COPD, CHF, chronic pain, and multiple chronic conditions. | Better reporting of recruitment population and improved recruitment and retention practices. More trials in these populations.
Interventions
Lack of clarity as to which intervention components are important in achieving improvements. Few studies of group interventions using modern technologies such as mobile platforms and video-based interventions. | Head-to-head comparative trials. More trials of interventions using technologies allowing remote participation. Studies assessing whether use of such technologies to deliver interventions improves participation and retention rates.
Comparator
Relatively few studies with active comparison groups. | Comparative effectiveness trials. For example, studies showing that mailed and phone-based self-management education programs were as effective as in-person group visits are interesting and point to alternative educational forums that may appeal to patients with time or geographic constraints. Also, more studies comparing individual to group-based education could better clarify the relative merits of each approach.
Outcomes
Studies evaluated dozens of different outcomes, many of which were non-standardized metrics of uncertain validity | Standardized approach to outcome measurement and use of well validated scales.
Timing
Lack of studies examining long-term outcomes. Few trials assessed the effects of booster sessions. | Trials with longer-term follow-up. Trials evaluating the effects and timing of booster sessions.
Setting
Few trials in community and rural settings | Test telehealth trials of group visits and trials located in community settings such as churches and community centers.

## CONCLUSION

A large number of studies have evaluated group visit interventions in a variety of patient populations. Intervention characteristics and effects differed depending on the chronic illness in which they were studied. Overall, group visits have the potential to improve patient self-efficacy, though there is little consistent data that they improve health, utilization, or quality of life outcomes. Group visits may be as effective as individual education visits and may represent a reasonable alternative for educating patients with chronic illness, though the varied and sometimes low participation and retention rates suggest they should not be the sole alternative.